# Appendix B Evidence Tables

Appendix B1 Data Abstraction of Screening Questionnaire Studies

Appendix B2 Data Abstraction of Capillary Screening Studies

Appendix B3 Data Abstraction of Childhood Treatment Trials