# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Screening

#### Database: Ovid MEDLINE (R) 1946 to March Week 2, 2017

1. exp Lead/
2. exp Lead Poisoning/
3. 1 or 2
4. exp mass screening/
5. exp “Surveys and Questionnaires”/
6. exp risk/
7. 4 or 5 or 6
8. 3 and 7
9. limit 8 to (“all infant (birth to 23 months)” or “preschool child (2 to 5 years)”)
10. exp pregnancy/
11. exp pregnancy complications/
12. exp fetus/
13. exp prenatal care/
14. exp Prenatal Exposure Delayed Effects/
15. exp Prenatal Injuries/
16. exp “Embryonic and Fetal Development”/
17. 10 or 11 or 12 or 13 or 14 or 15 or 16
18. 8 and 17
19. 9 or 18
20. ((test* or assay* or sampl* or detect* or surveil* or screen* or questionnair* or survey* or (risk* adj3 (assess* or predict* or determin* or measur* or calculat*))) adj5 (lead or pb) adj7 (infan* or fetus or fetal* or prenat* or pregnan* or baby or babies or child* or toddler*)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms]
21. 19 or 20
22. exp diagnosis/
23. 3 and 22
24. 17 and 23
25. limit 24 to (“all infant (birth to 23 months)” or “preschool child (2 to 5 years)”)
26. 24 or 25
27. ((test* or assay* or sampl* or detect* or surveil* or screen* or questionnair* or survey* or (risk* adj3 (assess* or predict* or determin* or measur* or calculat*))) adj5 (lead or pb) adj7 (infan* or fetus or fetal* or prenat* or pregnan* or baby or babies or child* or toddler*)).mp.
28. 17 and 27
29. limit 27 to (“all infant (birth to 23 months)” or “preschool child (2 to 5 years)”)
30. 28 or 29
31. 26 or 30
32. 21 or 31
33. limit 32 to humans
34. limit 33 to english language
35. limit 33 to abstracts
36. 34 or 35
37. remove duplicates from 36
38. limit 37 to yr=“2002-Current”
39. limit 37 to yr=“1902-2001”

### Treatment

#### Database: Ovid MEDLINE (R) 1946 to March Week 2, 2017

1. exp Lead Poisoning/dh, dt, nu, su, th [Diet Therapy, Drug Therapy, Nursing, Surgery, Therapy]
2. exp Lead/ae, to [Adverse Effects, Toxicity]
3. ((treat* or therap* or interven* or counsel* or antidot* or remed* or cure or cured or curing or cures or chelat*) adj7 (lead or pb) adj5 (poison* or toxic* or intoxic* or ((high* or elevat*) adj3 level*))).mp.
4. exp Lead Poisoning/ or exp Lead/
5. 3 and 4
6. 1 or 5
7. exp Therapeutics/
8. (th or dt or dh).fs.
9. exp counseling/
10. exp health education/
11. 7 or 8 or 9 or 10
12. 4 and 11
13. 6 or 12
14. limit 13 to humans
15. limit 14 to english language
16. limit 14 to abstracts
17. 15 or 16
18. remove duplicates from 17
19. limit 18 to (“all infant (birth to 23 months)” or “preschool child (2 to 5 years)”)
20. exp Pregnancy/
21. exp Pregnancy Complications/
22. exp fetus/
23. exp prenatal care/
24. exp Prenatal Exposure Delayed Effects/
25. exp Prenatal Injuries/
26. exp “Embryonic and Fetal Development”/
27. 20 or 21 or 22 or 23 or 24 or 25 or 26
28. 14 and 27
29. 19 or 28
30. 18 not 29

### Screening and Treatment

#### Database: Cochrane Database of Systematic Reviews 2005 to April 19, 2017

1. ((treat* or therap* or interven* or antidot* or remed* or cure or cured or curing or cures or chelat*) adj7 (lead or pb) adj5 (poison* or toxic* or intoxic* or ((high* or elevat*) adj3 level*))).mp.
2. ((screen* or ((routin* or annual* or yearly) adj5 (test* or diagnos* or assay* or exam*))) adj7 ((lead or pb) adj5 (poison* or toxic* or intoxic* or ((high* or elevat*) adj3 level*)))).mp. [mp=title, abstract, full text, keywords, caption text]
3. 1 or 2

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials through March 2017

1. ((treat* or therap* or interven* or antidot* or remed* or cure or cured or curing or cures or chelat*) adj7 (lead or pb) adj5 (poison* or toxic* or intoxic* or ((high* or elevat*) adj3 level*))).mp.
2. ((screen* or ((routin* or annual* or yearly) adj5 (test* or diagnos* or assay* or exam*))) adj7 ((lead or pb) adj5 (poison* or toxic* or intoxic* or ((high* or elevat*)
3. 1 or 2

## Appendix A2 Inclusion and Exclusion Criteria

| Include | Exclude
Populations | All KQs: Asymptomatic children age ≤5 years | All other populations^*^
Screening tests | KQs 1, 3: Measurement of blood lead level (using any method) with or without screening questionnaires or risk prediction tools; KQ 2a: Questionnaires or risk prediction tools that identify children who are more or less likely to have elevated blood lead levels (defined by a minimum threshold of 5 µg/dL); KQ 2b: Measurement of BLLs using capillary blood sampling | All other screening tests, including point-of-care blood lead level assays that are not approved by the U.S. Food and Drug Administration and are not available in the United States
Interventions | KQs 4–6: Studies assessing interventions aimed at reducing blood lead levels, including one or more of the following: counseling families to reduce lead exposure, nutritional interventions, residential hazard control techniques, and chelation therapy | Policies, laws, or community-based interventions focused on the primary prevention of lead exposure
Comparisons | KQs 1, 3: Screened vs. nonscreened groups; KQ 2a: Measurement of blood lead levels using venous blood sampling; KQ 2b: Studies on accuracy of capillary sampling to detect elevated blood lead levels must include a comparison with venous sampling; KQs 4–6: Treatment vs. placebo, inactive control, or no treatment | All other comparisons, including head-to-head comparisons of two different interventions
Outcomes | KQs 1, 5: Validated measures of cognitive and neurobehavioral outcomes in children, including assessment of IQ or development^†^; KQ 2a: Sensitivity, specificity, discrimination, and calibration; KQ 2b: Sensitivity, specificity, discrimination, calibration and measures of diagnostic accuracy; KQ 3: Anxiety, distress, pain, or discomfort related to venous or capillary blood sampling; false-positive results or blood lead levels <5 µg/dL, leading to repeat testing, unnecessary treatment, or both; KQ 4: Blood lead levels^†^; KQ 6: Anxiety or distress; inconvenience associated with intervention (e.g., school absenteeism associated with followup testing); morbidity attributed to chelation therapy (e.g., renal toxicity, sensitivity reactions) | All other outcomes, including measures of household lead dust
Study designs | KQs 1, 4: RCTs; KQ 2a: Observational studies assessing the accuracy of screening questionnaires for predicting elevated blood lead levels; KQ 2b: Observational studies assessing the accuracy of capillary sampling to measure blood lead levels; KQ 3: RCTs, CCTs, and cohort studies; KQ 5: RCTs and CCTs; KQ 6: RCTs, CCTs, prospective cohort studies with a concurrent control group, and case-control studies | Systematic reviews,^‡^ case series, case reports, or comparison with historical controls
Quality | Studies rated good or fair quality | Studies rated poor quality
Clinical Setting | Settings applicable to U.S. primary care settings, including pediatric outpatient clinics, community health clinics, and school-based clinics; KQs 4–6: The above plus settings referable from primary care settings | All other settings, including community health case-finding (e.g., blood lead level monitoring after known environmental exposure)
Country Setting | KQs 1-3: Research conducted in the United States or in populations similar to U.S. populations with services and interventions applicable to U.S. practice (i.e., countries with a United Nations Human Development Index of “very high” or “high” when no other evidence is available); KQs 4–6: Any country | KQs 1–3: Research not relevant to the United States or conducted in countries with a Human Development Index other than “very high”
Language | English language | Languages other than English

Abbreviations: CCT=controlled clinical trial; IQ=intelligence quotient; KQs=Key Questions; RCT=randomized, controlled trial; U.S.=United States.

* Studies enrolling older children were eligible if at least 50% of the sample was age ≤5 years, or if studies report outcomes separately for children age ≤5 years.

† We included outcomes measured in family members (e.g., siblings, pregnant women in the same household) subsequently identified as having elevated blood lead levels after the index family member was found to have an elevated blood lead level during screening.

‡ Systematic reviews were excluded from the evidence review. However, we conducted a separate search to identify relevant systematic reviews published since the last review to ensure that our database searches have captured all relevant studies. We describe relevant systematic reviews in the Discussion section of the report.

## Appendix A3 Literature Flow Diagram

* Other sources include prior reports, targeted searches for contextual questions, reference lists of relevant articles, and systematic reviews. Publications may be included for more than one Key Question.

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the present review. The diagram shows that 3,147 abstracts of potentially relevant articles were identified by a research librarian. 233 articles were reviewed at the full-text level after excluding 2,914 nonrelevant abstracts and background articles. From the 233 articles reviewed for inclusion, 17 were excluded due to wrong population, 27 due to wrong intervention, 24 due to wrong outcome, 26 due to wrong comparator, 43 due to wrong study design for key question, 64 due to wrong publication type (not a study), 6 due to non-English language but possibly relevant, 1 for poor-quality, and 1 due to being a systematic review or meta-analysis used only as a source document. After excluding these studies, 24 publications were included that provide evidence for any of the Key Questions. The following numbers of publications were included: 9 for Key Question 2a, 4 for Key Question 2b, 10 for Key Question 4, 3 for Key Question 5, and 3 for Key Question 6. No studies were included for Key Questions 1 or 3.

## Appendix A4 List of Included Studies

1 Anonymous. Safety and efficacy of succimer in toddlers with blood lead levels of 20-44 microg/dL. Treatment of Lead-Exposed Children (TLC) Trial Group. Pediatr Res. 2000;48(5):593–9. doi: 10.1203/00006450-200011000-00007. PMID: 11044477.11044477
2 Boreland F, Lesjak M, Lyle D. Evaluation of home lead remediation in an Australian mining community. Sci Total Environ. 2009;408(2):202–8. doi: 10.1016/j.scitotenv.2009.10.013. PMID: 19853886.19853886
3 Brown MJ, McLaine P, Dixon S, . A randomized, community-based trial of home visiting to reduce blood lead levels in children. Pediatrics. 2006;117(1):147–53. doi: 10.1542/peds.2004-2880. PMID: 16396872.16396872
4 Casey R, Wiley C, Rutstein R, . Prevalence of lead poisoning in an urban cohort of infants with high socioeconomic status. Clin Pediatr. 1994;33(8):480–4. PMID: 7955789.7955789
5 Dalton MA, Sargent JD, Stukel TA. Utility of a risk assessment questionnaire in identifying children with lead exposure. Arch Pediatr Adolesc Med. 1996;150(2):197–202. PMID: 8556126.8556126
6 Dietrich KN, Ware JH, Salganik M, . Effect of chelation therapy on the neuropsychological and behavioral development of lead-exposed children after school entry. Pediatrics. 2004;114(1):19–26. PMID: 15231903.15231903
7 France EK, Gitterman BA, Melinkovich P, . The accuracy of a lead questionnaire in predicting elevated pediatric blood lead levels. Arch Pediatr Adolesc Med. 1996;150(9):958–63. PMID: 8790128.8790128
8 Holmes SE, Drutz JE, Buffone GJ, . Blood lead levels in a continuity clinic population. J Toxicol Clin Toxicol. 1997;35(2):181–6. PMID: 9120888.9120888
9 Holtrop TG, Yee HY, Simpson PM, . A community outreach lead screening program using capillary blood collected on filter paper. Arch Pediatr Adolesc Med. 1998;152(5):455–8. PMID: 9605028.9605028
10 Kazal LA, Jr. The failure of CDC screening questionnaire to efficiently detect elevated lead levels in a rural population of children. J Fam Pract. 1997;45(6):515–8. PMID: 9420588.9420588
11 Liu X, Dietrich KN, Radcliffe J, . Do children with falling blood lead levels have improved cognition? Pediatrics. 2002;110(4):787–91. PMID: 12359796.12359796
12 Markowitz ME, Sinnett M, Rosen JF. A randomized trial of calcium supplementation for childhood lead poisoning. Pediatrics. 2004;113(1 Pt 1):e34–9. PMID: 14702492.14702492
13 Muniz MA, Dundas R, Mahoney MC. Evaluation of a childhood lead questionnaire in predicting elevated blood lead levels in a rural community. J Rural Health. 2003;19(1):15–9. PMID: 12585770.12585770
14 Nicholson JS. A community-based intervention for low-income families to reduce children’s blood lead levels between 3–9.9 μg/Dl. Children’s Health Care. 2017:1–18. doi: 10.1080/02739615.2017.1370673.
15 O’Connor ME, Rich D. Children with moderately elevated lead levels: is chelation with DMSA helpful? Clin Pediatr (Phila). 1999;38(6):325–31. doi: 10.1177/000992289903800602. PMID: 10378089.10378089
16 Parsons PJ, Raciti K, Esernio-Jenssen D. Evaluation and improvement of sample collection procedures for the determination of blood lead Center for Disease Control and Prevention. Atlanta: Centers for Disease Control and Prevention: 1993.
17 Robin LF, Beller M, Middaugh JP. Statewide assessment of lead poisoning and exposure risk among children receiving Medicaid services in Alaska. Pediatrics. 1997;99(4):E9. PMID: 9099784.9099784
18 Rogan WJ, Dietrich KN, Ware JH, . The effect of chelation therapy with succimer on neuropsychological development in children exposed to lead. N Engl J Med. 2001;344(19):1421–6. doi: 10.1056/NEJM200105103441902. PMID: 11346806.11346806
19 Sargent JD, Dalton MA. Rethinking the threshold for an abnormal capillary blood lead screening test. Arch Pediatr Adolesc Med. 1996;150(10):1084–8. PMID: 8859143.8859143
20 Schaffer SJ, Kincaid MS, Endres N, . Lead poisoning risk determination in a rural setting. Pediatrics. 1996;97(1):84–90. PMID: 8545231.8545231
21 Schlenker TL, Fritz CJ, Mark D, . Screening for pediatric lead poisoning. Comparability of simultaneously drawn capillary and venous blood samples. JAMA. 1994;271(17):1346–8. PMID: 8158820.8158820
22 Shannon M, Graef J, Lovejoy FH, Jr. Efficacy and toxicity of D-penicillamine in low-level lead poisoning. J Pediatr. 1988;112(5):799–804. PMID: 3361395.3361395
23 Snyder DC, Mohle-Boetani JC, Palla B, . Development of a population-specific risk assessment to predict elevated blood lead levels in Santa Clara County, California. Pediatrics. 1995;96(4 Pt 1):643–8. PMID: 7567324.7567324
24 Tejeda DM, Wyatt DD, Rostek BR, . Do questions about lead exposure predict elevated lead levels? Pediatrics. 1994;93(2):192–4. PMID: 8121730.8121730
25 Wolf AW, Jimenez E, Lozoff B. Effects of iron therapy on infant blood lead levels. J Pediatr. 2003;143(6):789–95. doi: 10.1067/S0022-3476(03)00540-7. PMID: 14657829.14657829

## Appendix A5 List of Excluded Studies

1 Abendroth K. [Excellent effect of sodium-citrate-EDTA-combination therapy in severe lead poisoning during pregnancy]. Dtsch Gesundheitsw. 1971;26(45):2130–1. PMID: 5004297. Excluded: Not English language, but possibly relevant.5004297
2 Alfaro C, Vincelet C, Lombrail P, . [Evaluation of the screening strategy for lead poisoning in 1-to-3-year-old children monitored in maternal-child welfare centers in Paris]. Rev Epidemiol Sante Publique. 1993;41(6):473–9. PMID: 8296033. Excluded: Not English language, but possibly relevant.8296033
3 Alpert JJ. Screening for lead poisoning. Pediatrics. 1970;45(4):721–2. PMID: 5438185. Excluded: Not a study.5438185
4 Altmann P, Maruna RF, Maruna H, . [Lead detoxication effect of a combined calcium phosphate and ascorbic acid therapy in pregnant women with increased lead burden (author’s transl)]. Wien Med Wochenschr. 1981;131(12):311–4. PMID: 7293190. Excluded: Not English language, but possibly relevant.7293190
5 Anderson MK, Amrich M, Decker KL, . Using state lead poisoning surveillance system data to assess false positive results of capillary testing. Matern Child Health J. 2007;11(6):603–10. doi: 10.1007/s10995-007-0196-1. PMID: 17340181. Excluded: Wrong study design for Key Question.17340181
6 Andrews KW, Savitz DA, Hertz-Picciotto I. Prenatal lead exposure in relation to gestational age and birth weight: a review of epidemiologic studies. Am J Ind Med. 1994;26(1):13–32. PMID: 8074121. Excluded: Not a study.8074121
7 Anonymous. The Treatment of Lead-exposed Children (TLC) trial: design and recruitment for a study of the effect of oral chelation on growth and development in toddlers. Paediatr Perinat Epidemiol. 1998;12(3):313–33. PMID: 9690266. Excluded: Not a study.9690266
8 Arbuckle TE, Liang CL, Morisset AS, . Maternal and fetal exposure to cadmium, lead, manganese and mercury: The MIREC study. Chemosphere. 2016;163:270–82. doi: 10.1016/j.chemosphere.2016.08.023. PMID: 27540762. Excluded: Wrong study design for Key Question.27540762
9 Aschengrau A, Beiser A, Bellinger D, . The impact of soil lead abatement on urban children’s blood lead levels: phase II results from the Boston Lead-In-Soil Demonstration Project. Environ Res. 1994;67(2):125–48. doi: 10.1006/enrs.1994.1069. PMID: 7982389. Excluded: Wrong intervention.7982389
10 Aschengrau A, Hardy S, Mackey P, . The impact of low technology lead hazard reduction activities among children with mildly elevated blood lead levels. Environ Res. 1998;79(1):41–50. doi: 10.1006/enrs.1998.3858. PMID: 9756679. Excluded: Wrong outcome.9756679
11 Awasthi S, Awasthi R, Srivastav RC. Maternal blood lead level and outcomes of pregnancy in Lucknow, North India. Indian Pediatr. 2002;39(9):855–60. PMID: 12368533. Excluded: Wrong study design for Key Question.12368533
12 Baghurst PA, Robertson EF, McMichael AJ, . The Port Pirie Cohort Study: lead effects on pregnancy outcome and early childhood development. Neurotoxicology. 1987;8(3):395–401. PMID: 2443882. Excluded: Wrong study design for Key Question.2443882
13 Bajorek MM. Screening children for lead poisoning. West J Med. 1995;163(1):64. PMID: 7667984. Excluded: Not a study.7667984
14 Baloh R, Sturm R, Green B, . Neuropsychological effects of chronic asymptomatic increased lead absorption. A controlled study. Arch Neurol. 1975;32(5):326–30. PMID: 1137507. Excluded: Wrong study design for Key Question.1137507
15 Bartsocas CS, Grunt JA, Boylen GW, Jr., . Oral D-penicillamine and intramuscular BAL+EDTA in the treatment of lead accumulation. Acta Paediatr Scand. 1971;60(5):553–8. PMID: 4999890. Excluded: Wrong study design for Key Question.4999890
16 Batagol R. Australian Drug Evaluation Committee: Medicines in pregnancy-An Australian categorisation of risk of drug use in pregnancy, 4th. Australian Government Publishing Service, Canberra, Australia; 1999. Excluded: Not a study.
17 Beck RB, Rosenbaum, KN, Byers PH, . Ultrastructural findings in fetal penicillamine syndrome. Presentation and abstract, March of Dimes 14th Annual Birth Defects Conference, San Diego, CA; 1981. Excluded: Wrong outcome.
18 Bellinger D. Prenatal/early postnatal exposure to lead and risk of developmental impairment. Birth Defects Orig Artic Ser. 1989;25(6):73–97. PMID: 2481518. Excluded: Not a study.2481518
19 Bellinger DC, Stiles KM, Needleman HL. Low-level lead exposure, intelligence and academic achievement: a long-term follow-up study. Pediatrics. 1992;90(6):855–61. PMID: 1437425. Excluded: Wrong study design for Key Question.1437425
20 Benson PF, Chisolm JJ, Jr. A reliable qualitative urine coproporphyrin test for lead intoxication in young children. J Pediatr. 1960;56:759–67. PMID: 13799015. Excluded: Wrong intervention.13799015
21 Besunder JB, Super DM, Anderson RL. Comparison of dimercaptosuccinic acid and calcium disodium ethylenediaminetetraacetic acid versus dimercaptopropanol and ethylenediaminetetraacetic acid in children with lead poisoning. J Pediatr. 1997;130(6):966–71. PMID: 9202621. Excluded: Wrong comparator.9202621
22 Bhattacharya A, Shukla R, Auyang ED, . Effect of succimer chelation therapy on postural balance and gait outcomes in children with early exposure to environmental lead. Neurotoxicology. 2007;28(3):686–95. doi: 10.1016/j.neuro.2007.03.007. PMID: 17499360. Excluded: Wrong outcome.17499360
23 Binns HJ, Kim D, Campbell C. Targeted screening for elevated blood lead levels: populations at high risk. Pediatrics. 2001;108(6):1364–6. PMID: 11731660. Excluded: Not a study.11731660
24 Binns HJ, LeBailly SA, Fingar AR, . Evaluation of risk assessment questions used to target blood lead screening in Illinois. Pediatrics. 1999;103(1):100–6. PMID: 9917446. Excluded: Wrong comparator.9917446
25 Binns HJ, LeBailly SA, Poncher J, . Is there lead in the suburbs? Risk assessment in Chicago suburban pediatric practices. Pediatric Practice Research Group. Pediatrics. 1994;93(2):164–71. PMID: 8121725. Excluded: Wrong comparator.8121725
26 Blanksma LA, Sachs HK, Murray EF, . Failure of the urinary delta-aminolevulinic acid test to detect pediatric lead poisoning. Am J Clin Pathol. 1970;53(6):956–62. PMID: 5515391. Excluded: Wrong intervention.5515391
27 Blumenthal S, Davidow B, Harris D, . A comparison between two diagnostic tests for lead poisoning. Am J Public Health. 1972;62(8):1060–4. PMID: 5046445. Excluded: Wrong intervention.5046445
28 Borja-Aburto VH, Hertz-Picciotto I, Rojas Lopez M, . Blood lead levels measured prospectively and risk of spontaneous abortion. Am J Epidemiol. 1999;150(6):590–7. PMID: 10489998. Excluded: Wrong study design for Key Question.10489998
29 Bossarte RM, Brown MJ, Jones RL. Blood lead misclassification due to defective LeadCare blood lead testing equipment. Clin Chem. 2007;53(5):994–5. doi: 10.1373/clinchem.2006.082404. PMID: 17468412. Excluded: Not a study.17468412
30 Bouhouch RR, El-Fadeli S, Andersson M, . Effects of wheat-flour biscuits fortified with iron and EDTA, alone and in combination, on blood lead concentration, iron status, and cognition in children: a double-blind randomized controlled trial. Am J Clin Nutr. 2016;104(5):1318–26. doi: 10.3945/ajcn.115.129346. PMID: 27733396. Excluded: Wrong intervention.27733396
31 Bradberry S, Vale A. Dimercaptosuccinic acid (succimer; DMSA) in inorganic lead poisoning. Clin Toxicol. 2009;47(7):617–31. doi: 10.1080/15563650903174828. PMID: 19663612. Excluded: Not a study.19663612
32 Bradley JE, Baumgartner RJ. Subsequent mental development of children with lead encephalopathy, as related to type of treatment. J Pediatr. 1958;53(3):311–5. PMID: 13576382. Excluded: Wrong population.13576382
33 Braun JM, Hornung R, Chen A, . Effect of Residential Lead-Hazard Interventions on Childhood Blood Lead Concentrations and Neurobehavioral Outcomes: A Randomized Clinical Trial. JAMA Pediatr. 2018;172(10):934–42. doi: 10.1001/jamapediatrics.2018.2382. PMID: 30178064. Excluded: Wrong intervention.30178064
34 Briss PA, Rosenblum LS. Screening strategies for lead poisoning. JAMA. 1993;270(21):2556; author reply -7. PMID: 8230637. Excluded: Not a study.8230637
35 Bronson MA, Renier CM. The location of residence as a basis for childhood lead poisoning screening programs. Am J Public Health. 1995;85(4):589–90. PMID: 7702132. Excluded: Not a study.7702132
36 Browder A, Joselow M, Foster J. Screening for detection of childhood lead poisoning in Newark. J Med Soc N J. 1974;71(1):45–8. PMID: 4520978. Excluded: Not a study.4520978
37 Browder A, Joselow M, Louria DB, . Evaluation of screening programs for childhood lead poisoning by analysis of hospital admissions. Am J Public Health. 1974;64(9):914–5. PMID: 4425003. Excluded: Not a study.4425003
38 Brown MJ, Meehan PJ. Health effects of blood lead levels lower than 10 mg/dl in children. Am J Public Health. 2004;94(1):8–9; author reply PMID: 14713682. Excluded: Not a study.14713682
39 Brown SJ. Treatment and prevention of childhood lead poisoning: new approach. Wis Med J. 1973;72(8):175–7. PMID: 4199056. Excluded: Not a study.4199056
40 Burke BL, Jr. Lead poisoning treatment. J Pediatr. 2006;149(3):428; author reply -9. doi: 10.1016/j.jpeds.2006.02.030. PMID: 16939771. Excluded: Not a study.16939771
41 Burns MS, Shah LH, Marquez ER, . Efforts to identify at-risk children for blood lead screening in pediatric clinics-Clark County, Nevada. Clin Pediatr 2012;51(11):1048–55. doi: 10.1177/0009922812458352. PMID: 22935218. Excluded: Wrong outcome.22935218
42 Byers RK, Maloof C. Edathamil calcium-disodium (versenate) in treatment of lead poisoning in children. AMA Am J Dis Child. 1954;87(5):559–69. PMID: 13157613. Excluded: Wrong study design for Key Question.13157613
43 Campbell C, Gracely E, Tran M, . Primary prevention of lead exposure-blood lead results at age two years. Int J Environ Res Public Health. 2012;9(4):1216–26. doi: 10.3390/ijerph9041216. PMID: 22690192. Excluded: Wrong outcome.22690192
44 Campbell C, Tran M, Gracely E, . Primary prevention of lead exposure: the Philadelphia lead safe homes study. Public Health Rep. 2011;126: Suppl 1:76–88. PMID: 21563715. Excluded: Wrong population.21563715
45 Campbell JR, Schaffer SJ. Predicting the outcome of the CaNa2EDTA challenge test in children with moderately elevated blood lead levels. Environ Health Perspect. 1999;107(6):437–40. PMID: 10339443. Excluded: Wrong intervention.10339443
46 Carpenter JW. Pediatric lead level screening. Alaska Med. 1993;35(2):173. PMID: 8238773. Excluded: Wrong study design for Key Question.8238773
47 Casey R, Wiley C, Rutstein R, . Longitudinal assessment for lead poisoning. Clin Pediatr 1996;35(2):58–61. PMID: 8775476. Excluded: Wrong intervention.8775476
48 Centers for Disease Control and Prevention. Blood lead levels among children in a managed-care organization-California, October 1992-March 1993. MMWR. 1995;44(34):627–9, 35. PMID: 7643848. Excluded: Wrong outcome.7643848
49 Chen A, Rhoads GG, Cai B, . The effect of chelation on blood pressure in lead-exposed children: a randomized study. Environ Health Perspect. 2006;114(4):579–83. PMID: 16581549. Excluded: Wrong outcome.16581549
50 Chen A, Schwarz D, Radcliffe J, . Maternal IQ, child IQ, behavior, and achievement in urban 5-7 year olds. Pediatr Res. 2006;59(3):471–7. doi: 10.1203/01.pdr.0000199910.16681.f0. PMID: 16492992. Excluded: Wrong study design for Key Question.16492992
51 Chisolm JJ, Jr. Chronic lead intoxication in children. Dev Med Child Neurol. 1965;7(5):529–36. PMID: 4956085. Excluded: Not a study.4956085
52 Chisolm JJ, Jr. The use of chelating agents in the treatment of acute and chronic lead intoxication in childhood. J Pediatr. 1968;73(1):1–38. PMID: 4969284. Excluded: Not a study.4969284
53 Chisolm JJ. Screening techniques for undue lead exposure in children: biological and practical considerations. J Pediatr. 1971;79(5):719–25. PMID: 4941955. Excluded: Not a study.4941955
54 Chisolm JJ, Jr. Treatment of lead poisoning. Mod Treat. 1971;8(3):593–611. PMID: 5001054. Excluded: Not a study.5001054
55 Chisolm JJ, Jr. Screening for lead poisoning in children. Pediatrics. 1973;51(2):280–3. PMID: 4695862. Excluded: Not a study.4695862
56 Chisolm JJ, Jr. Management of increased lead absorption and lead poisoning in children. N Engl J Med. 1973;289(19):1016–8. doi: 10.1056/NEJM197311082891906. PMID: 4742201. Excluded: Not a study.4742201
57 Chisolm JJ, Jr. Chelation therapy in children with subclinical plumbism. Pediatrics. 1974;53(3):441–3. PMID: 4205583. Excluded: Not a study.4205583
58 Chisolm JJ, Jr. BAL, EDTA, DMSA and DMPS in the treatment of lead poisoning in children. J Toxicol Clin Toxicol. 1992;30(4):493–504. PMID: 1331490. Excluded: Not a study.1331490
59 Chisolm JJ, Jr., Harrison HE. The treatment of acute lead encephalopathy in children. Pediatrics. 1957;19(1):2–20. PMID: 13400575. Excluded: Wrong population.13400575
60 Chisolm JJ, Jr., Kaplan E. Lead poisoning in childhood-comprehensive management and prevention. J Pediatr. 1968;73(6):942–50. PMID: 4972778. Excluded: Not a study.4972778
61 Chisolm JJ, Jr., Mellits ED, Keil JE, . A simple protoporphyrin assay-microhematocrit procedure as a screening technique for increased lead absorption in young children. J Pediatr. 1974;84(4):490–6. PMID: 4834244. Excluded: Wrong intervention.4834244
62 Chisolm JJ, Jr., Thomas DJ. Use of 2,3-dimercaptopropane-1-sulfonate in treatment of lead poisoning in children. J Pharmacol Exp Ther. 1985;235(3):665–9. PMID: 4078728. Excluded: Wrong comparator.4078728
63 Chomchai C, Padungtod C, Chomchai S. Predictors of elevated blood lead level in Thai children: a pilot study using risk assessment questionnaire. J Med Assoc Thai. 2005;88: Suppl 8:S53–9. PMID: 16856427. Excluded: Wrong outcome.16856427
64 Clark S, Grote J, Wilson J, . Occurrence and determinants of increases in blood lead levels in children shortly after lead hazard control activities. Environ Res. 2004;96(2):196–205. doi: 10.1016/j.envres.2003.11.006. PMID: 15325880. Excluded: Wrong comparator.15325880
65 Clinical and Laboratory Standards Institute. Measurement procedures for the determination of lead concentrations in blood and urine. Second ed; 2013. Excluded: Not a study.
66 Coffin R, Phillips JL, Staples WI, . Treatment of lead encephalopathy in children. J Pediatr. 1966;69(2):198–206. PMID: 4957770. Excluded: Wrong population.4957770
67 Cooke RE, Glynn KL, Ullmann WW, . Comparative study of a micro-scale test for lead in blood, for use in mass screening programs. Clin Chem. 1974;20(5):582–5. PMID: 4826953. Excluded: Wrong intervention.4826953
68 Council on Environmental Health. Prevention of childhood lead toxicity. Pediatrics. 2016;138(1) doi: 10.1542/peds.2016-1493. Excluded: Not a study.
69 Counter SA, Ortega F, Shannon MW, . Succimer (meso-2,3-dimercaptosuccinic acid (DMSA)) treatment of Andean children with environmental lead exposure. Int J Occup Environ Health. 2003;9(2):164–8. doi: 10.1179/oeh.2003.9.2.164. PMID: 12848245. Excluded: Wrong population.12848245
70 Creighton S, Hafner JW, Aldag JC. Effectiveness of a pediatric verbal lead exposure screening protocol in emergency department patients. Pediatr Emerg Care. 2013;29(2):156–61. doi: 10.1097/PEC.0b013e3182808abe. PMID: 23364376. Excluded: Wrong outcome.23364376
71 Davis JR. Reliability of urinary delta-aminolevulinic acid as a mass screening technic for childhood exposure to lead. Am J Clin Pathol. 1970;53(6):967–9. PMID: 5509833. Excluded: Not a study.5509833
72 De la Burde B, Choate MS, Jr. Does asymptomatic lead exposure in children have latent sequelae? J Pediatr. 1972;81(6):1088–91. PMID: 4643025. Excluded: Wrong study design for Key Question.4643025
73 DeBaun MR, Sox HC, Jr. Setting the optimal erythrocyte protoporphyrin screening decision threshold for lead poisoning: a decision analytic approach. Pediatrics. 1991;88(1):121–31. PMID: 2057248. Excluded: Wrong intervention.2057248
74 Delves HT. Blood collection for screening children for exposure to lead. Clin Chem. 1996;42(6 Pt 1):983–5. PMID: 8665698. Excluded: Not a study.8665698
75 Dillard RA. Detection, evaluation, and management of children exposed to lead. Texas Med. 1978;74(11):65–8. PMID: 725776. Excluded: Not a study.725776
76 Donahue LA, Brennan GG. Lyophilized urea in Traverts solution for the treatment of lead encephalopathy. J Med Soc N J. 1962;59:456–9. PMID: 13887157. Excluded: Wrong population.13887157
77 Dyal B. Are lead risk questionnaires adequate predictors of blood lead levels in children? Public Health Nurs. 2012;29(1):3–10. doi: 10.1111/j.1525-1446.2011.00961.x. PMID: 22211746. Excluded: Wrong comparator.22211746
78 Edwards KS, Forsyth BW. Lead screening at pediatric teaching programs. Am J Dis Child. 1989;143(12):1455–7. PMID: 2589277. Excluded: Wrong outcome.2589277
79 Esernio-Jenssen D, Bush V, Parsons PJ. Evaluation of VACUTAINER PLUS Low Lead tubes for blood lead and erythrocyte protoporphyrin testing. Clin Chem. 1999;45(1):148–50. PMID: 9895358. Excluded: Not a study.9895358
80 Esteban E, Rubin CH, Jones RL, . Hair and blood as substrates for screening children for lead poisoning. Arch Environ Health. 1999;54(6):436–40. doi: 10.1080/00039899909603376. PMID: 10634234. Excluded: Wrong intervention.10634234
81 Etchevers A, Glorennec P, Le Strat Y, . Screening for elevated blood lead levels in children: assessment of criteria and a proposal for new ones in France. Int J Environ Res Public Health. 2015;12(12):15366–78. doi: 10.3390/ijerph121214989. PMID: 26633457. Excluded: Wrong outcome.26633457
82 Ettinger AS, Lamadrid-Figueroa H, Mercado-Garcia A, . Effect of calcium supplementation on bone resorption in pregnancy and the early postpartum: a randomized controlled trial in Mexican women. Nutr J. 2014;13(1):116. doi: 10.1186/1475-2891-13-116. PMID: 25511814. Excluded: Wrong outcome.25511814
83 Ettinger AS, Lamadrid-Figueroa H, Tellez-Rojo MM, . Effect of calcium supplementation on blood lead levels in pregnancy: a randomized placebo-controlled trial. Environ Health Perspect. 2009;117(1):26–31. doi: 10.1289/ehp.11868. PMID: 19165383. Excluded: Wrong population.19165383
84 Farrar HC, McLeane LR, Wallace M, . A comparison of two dosing regimens of succimer in children with chronic lead poisoning. J Clin Pharmacol. 1999;39(2):180–3. PMID: 11563411. Excluded: Wrong comparator.11563411
85 Fisher AA. Safety of ethylenediamine tetraacetate in the treatment of lead poisoning in persons sensitive to ethylenediamine hydrochloride. Cutis. 1991;48(2):105–6. PMID: 1935232. Excluded: Not a study.1935232
86 Friedlander MA, Brooks CT, Sheehe PR. Blood pressure and creatinine clearance in lead-exposed children: the effect of treatment. Arch Environ Health. 1981;36(6):310–5. PMID: 7316569. Excluded: Wrong comparator.7316569
87 Galke W, Clark S, Wilson J, . Evaluation of the HUD lead hazard control grant program: early overall findings. Environ Res. 2001;86(2):149–56. doi: 10.1006/enrs.2001.4259. PMID: 11437461. Excluded: Wrong comparator.11437461
88 Gardella C. Lead exposure in pregnancy: a review of the literature and argument for routine prenatal screening. Obstet Gynecol Surv. 2001;56(4):231–8. PMID: 11285436. Excluded: Not a study.11285436
89 Garza A. Screening strategies for lead poisoning. JAMA. 1993;270(21):2555; author reply 6-7. PMID: 8230634. Excluded: Not a study.8230634
90 Gause D, Chase W, Foster J, . Reduction in lead levels among children in Newark. J Med Soc N J. 1977;74(11):958–60. PMID: 269968. Excluded: Wrong study design for Key Question.269968
91 Gellert GA, Wagner GA, Maxwell RM, . Lead poisoning: from screening to primary prevention. Pediatrics. 1994;93(2):343–4. PMID: 8121754. Excluded: Not a study.8121754
92 Gemmel DJ. Use of the Centers for Disease Control and Prevention childhood lead poisoning risk questionnaire to predict blood lead elevations in pregnant women. Obstet Gynecol. 1996;88(1):159–60. doi: 10.1016/0029-7844(96)88088-4. PMID: 8684754. Excluded: Not a study.8684754
93 Ginot L, Fontaine A, Cheymol J, . [Evaluating the effectiveness of child lead poisoning prevention programs]. Rev Epidemiol Sante Publique. 2003;51(4):427–38. PMID: 13679735. Excluded: Not English language, but possibly relevant.13679735
94 Glotzer DE, Weitzman M, Aschengrau A, . Economic evaluation of environmental interventions for low-level childhood lead poisoning. Ambulatory Child Health. 1997;3(3):255–67. Excluded: Wrong outcome.
95 Goldman LR. Lead screening. Pediatrics. 1993;91(4):854–5. PMID: 8464688. Excluded: Not a study.8464688
96 Goodlad JK, Marcus DK, Fulton JJ. Lead and Attention-Deficit/Hyperactivity Disorder (ADHD) symptoms: a meta-analysis. Clin Psychol Rev. 2013;33(3):417–25. doi: 10.1016/j.cpr.2013.01.009. PMID: 23419800. Excluded: Wrong intervention.23419800
97 Graziano JH, Lolacono NJ, Meyer P. Dose-response study of oral 2,3-dimercaptosuccinic acid in children with elevated blood lead concentrations. J Pediatr. 1988;113(4):751–7. PMID: 2845043. Excluded: Wrong comparator.2845043
98 Graziano JH, Lolacono NJ, Moulton T, . Controlled study of meso-2,3-dimercaptosuccinic acid for the management of childhood lead intoxication. J Pediatr. 1992;120(1):133–9. PMID: 1309865. Excluded: Wrong comparator.1309865
99 Groleau V, Herold RA, Schall JI, . Blood lead concentration is not altered by high-dose vitamin D supplementation in children and young adults with HIV. J Pediatr Gastroenterol Nutr. 2013;56(3):316–9. doi: 10.1097/MPG.0b013e3182758c4a. PMID: 23059649. Excluded: Wrong population.23059649
100 Gutgesell ME. Lead screening in the general pediatric clinic. Va Med Q. 1996;123(3):190–1. PMID: 8752964. Excluded: Wrong comparator.8752964
101 Hankin L, Hanson KR, Kornfeld JM, . Simplified method for mass screening for lead poisoning based on delta-aminolevulinic acid in urine. Clin Pediatr. 1970;9(12):707–12. PMID: 5487477. Excluded: Wrong intervention.5487477
102 Hanna TL, Dietzler DN, Smith CH, . Erythrocyte porphyrin analysis in the detection of lead poisoning in children: evaluation of four micromethods. Clin Chem. 1976;22(2):161–8. PMID: 1248115. Excluded: Wrong intervention.1248115
103 Haust HL, Ali H, Haines DS, . Short-term administration of dimercaptopropanol (BAL) and calcium disodium edetate (EDTA) for diagnostic and therapeutic lead mobilization. Int J Biochem. 1980;12(5-6):897–904. PMID: 6778726. Excluded: Wrong population.6778726
104 Heavey E. Lead poisoning: When an entire community is exposed. Nursing. 2016;46(9):28–33. doi: 10.1097/01.NURSE.0000490212.15944.5e. PMID: 27556165. Excluded: Not a study.27556165
105 Hernandez-Avila M, Gonzalez-Cossio T, Hernandez-Avila JE, . Dietary calcium supplements to lower blood lead levels in lactating women: a randomized placebo-controlled trial. Epidemiology. 2003;14(2):206–12. doi: 10.1097/01.Ede.0000038520.66094.34. PMID: 12606887. Excluded: Wrong population.12606887
106 Hu H, Tellez-Rojo MM, Bellinger D, . Fetal lead exposure at each stage of pregnancy as a predictor of infant mental development. Environ Health Perspect. 2006;114(11):1730–5. PMID: 17107860. Excluded: Wrong study design for Key Question.17107860
107 Iniguez JL, Leverger G, Dollfus C, . Lead mobilization test in children with lead poisoning: validation of a 5-hour edetate calcium disodium provocation test. Arch Pediatr Adolesc Med. 1995;149(3):338–40. PMID: 7858698. Excluded: Wrong study design for Key Question.7858698
108 Jacobziner H, Raybin HW. Lead poisoning treated with bal. N Y State J Med. 1964;64:441. PMID: 14118322. Excluded: Not a study.14118322
109 Janakiraman V, Ettinger A, Mercado-Garcia A, . Calcium supplements and bone resorption in pregnancy: a randomized crossover trial. Am J Prev Med. 2003;24(3):260–4. PMID: 12657345. Excluded: Wrong outcome.12657345
110 Jin Y, Yu F, Liao Y, . Therapeutic efficiency of succimer used with calcium and ascorbic acid in the treatment of mild lead-poisoning. Environ Toxicol Pharmacol. 2011;31(1):137–42. doi: 10.1016/j.etap.2010.09.015. PMID: 21787678. Excluded: Wrong comparator.21787678
111 Jordan CM, Yust BL, Robison LL, . A randomized trial of education to prevent lead burden in children at high risk for lead exposure: efficacy as measured by blood lead monitoring. Environ Health Perspect. 2003;111(16):1947–51. PMID: 14644671. Excluded: Wrong intervention.14644671
112 Kahn CA, Kelly PC, Walker WO, Jr. Lead screening in children with attention deficit hyperactivity disorder and developmental delay. Clin Pediatr. 1995;34(9):498–501. PMID: 7586924. Excluded: Wrong population.7586924
113 Kalra V, Dua T, Kumar V, . Succimer in symptomatic lead poisoning. Indian Pediatr. 2002;39(6):580–5. PMID: 12084955. Excluded: Not a study.12084955
114 Kaplowitz SA, Perlstadt H, D’Onofrio G, . The predictive value of self-report questions in a clinical decision rule for pediatric lead poisoning screening. Public Health Rep. 2012;127(4):375–82. PMID: 22753980. Excluded: Wrong study design for Key Question.22753980
115 Kaplowitz SA, Perlstadt H, Perlstadt H, . Comparing lead poisoning risk assessment methods: census block group characteristics vs. zip codes as predictors. Public Health Rep. 2010;125(2):234–45. PMID: 20297750. Excluded: Wrong study design for Key Question.20297750
116 Kassner J, Shannon M, Graef J. Role of forced diuresis on urinary lead excretion after the ethylenediaminetetraacetic acid mobilization test. J Pediatr. 1990;117(6):914–6. PMID: 2123241. Excluded: Wrong intervention.2123241
117 Kaul B, Slavin G, Davidow B. Free erythrocyte protoporphyrin and zinc protoporphyrin measurements compared as primary screening methods for detection of lead poisoning. Clin Chem. 1983;29(8):1467–70. PMID: 6872205. Excluded: Wrong intervention.6872205
118 Kawatu D, Weinberger HL, Blatt SD. Universal versus selective screening for lead in children. Pediatrics. 1995;95(1):157–9. PMID: 7770298. Excluded: Not a study.7770298
119 Kegler MC, Malcoe LH. Results from a lay health advisor intervention to prevent lead poisoning among rural Native American children. Am J Public Health. 2004;94(10):1730–5. PMID: 15451742. Excluded: Wrong intervention.15451742
120 Kegler MC, Malcoe LH, Fedirko V. Primary prevention of lead poisoning in rural Native American children: behavioral outcomes from a community-based intervention in a former mining region. Fam Community Health. 2010;33(1):32–43. doi: 10.1097/FCH.0b013e3181c4e252. PMID: 20010003. Excluded: Wrong intervention.20010003
121 Kimbrough RD, LeVois M, Webb DR. Management of children with slightly elevated blood lead levels. Pediatrics. 1994;93(2):188–91. PMID: 8121729. Excluded: Wrong study design for Key Question.8121729
122 Knighton AJ, Payne NR, Speedie S. Lead Testing in a Pediatric Population: Underscreening and Problematic Repeated Tests. Journal of Public Health Management & Practice. 2016;22(4):331–7. doi: 10.1097/PHH.0000000000000344. PMID: 26418307. Excluded: Wrong outcome.26418307
123 Kornfeld JM, Ullmann WW, Hankin L. Modifications and use of the dipstick test, based on urinary delta-aminolevulinic acid (ALA), for the detection of lead poisoning in children. Clin Toxicol. 1972;5(1):7–16. doi: 10.3109/15563657208990503. PMID: 5043281. Excluded: Wrong intervention.5043281
124 Kotok D. Development of children with elevated blood lead levels: a controlled study. J Pediatr. 1972;80(1):57–61. PMID: 5016353. Excluded: Wrong study design for Key Question.5016353
125 Lanphear BP. The paradox of lead poisoning prevention. Science. 1998;281(5383):1617–8. PMID: 9767027. Excluded: Not a study.9767027
126 Lanphear BP. Childhood lead poisoning prevention: too little, too late. JAMA. 2005;293(18):2274–6. doi: 10.1001/jama.293.18.2274. PMID: 15886384. Excluded: Not a study.15886384
127 Liebelt EL, Shannon MW. Oral chelators for childhood lead poisoning. Pediatr Ann. 1994;23(11):616–9, 23–6. PMID: 7838614. Excluded: Not a study.7838614
128 Lin-Fu JS. Screening for lead poisoning. Pediatrics. 1970;45(4):720–1. PMID: 5438184. Excluded: Not a study.5438184
129 Lin-Fu JS. Diagnostic and screening procedures for lead poisoning. Pediatrics. 1971;48(3):488–9. PMID: 5094354. Excluded: Not a study.5094354
130 Lioy PJ, Yiin LM, Adgate J, . The effectiveness of a home cleaning intervention strategy in reducing potential dust and lead exposures. J Expo Anal Environ Epidemiol. 1998;8(1):17–35. PMID: 9470102. Excluded: Wrong outcome.9470102
131 Liu J, Gao D, Chen Y, . Lead exposure at each stage of pregnancy and neurobehavioral development of neonates. Neurotoxicology. 2014;44:1–7. doi: 10.1016/j.neuro.2014.03.003. PMID: 24704588. Excluded: Wrong study design for Key Question.24704588
132 Lockitch G. Perspectives on lead toxicity. Clin Biochem. 1993;26(5):371–81. PMID: 8299207. Excluded: Not a study.8299207
133 Mabry IR. Screening for elevated blood lead levels in children and pregnant women. Am Fam Phys. 2008;78(10):1201–2. PMID: 19035069. Excluded: Not a study.19035069
134 Madlock YS, Bradley E. Childhood lead poisoning prevention program Memphis and Shelby County Health Department. Tenn Med. 2002;95(10):418–20. PMID: 12369542. Excluded: Not a study.12369542
135 Mankikar D, Campbell C, Greenberg R. Evaluation of a home-based environmental and educational intervention to improve health in vulnerable households: Southeastern Pennsylvania lead and healthy homes program. Int J Environ Res Public Health. 2016;13(9):09. doi: 10.3390/ijerph13090900. PMID: 27618087. Excluded: Wrong intervention.27618087
136 Marcus M, Hollander M, Lucas RE, . Micro-scale blood lead determinations in screening: evaluation of factors affecting results. Clin Chem. 1975;21(4):533–6. PMID: 1116287. Excluded: Wrong study design for Key Question.1116287
137 Marcus SM. Treatment of lead-exposed children. Pediatrics. 1996;98(1):161–2; author reply 3. PMID: 8668396. Excluded: Not a study.8668396
138 Marcus SM, Joselow MM, Kemp F, . Warning: spurious elevations of blood lead in micro puncture techniques. J Pediatr. 1977;91(1):164. PMID: 874656. Excluded: Not a study.874656
139 Margulis HL. The control and prevention of pediatric lead poisoning in East Orange, New Jersey. J Environ Health. 1977;39(5):362–5. PMID: 10235755. Excluded: Not a study.10235755
140 Markiewicz T. Recognizing, treating, and preventing lead poisoning. Am J Nurs. 1993;93(10):59–62, 4. PMID: 8213948. Excluded: Not a study.8213948
141 Markowitz ME, Bijur PE, Ruff H, . Effects of calcium disodium versenate (CaNa2EDTA) chelation in moderate childhood lead poisoning. Pediatrics. 1993;92(2):265–71. PMID: 8337028. Excluded: Wrong study design for Key Question.8337028
142 Mazur LJ, Moyer VA, Lally PA, . Evaluation of a lead screening program in Houston, Tex. Tex Med. 1996;92(1):54–7. PMID: 8599168. Excluded: Wrong outcome.8599168
143 McCabe EB, Challop RS. Simple rapid test for lead poisoning. J Pediatr. 1972;80(5):893–4. PMID: 5018404. Excluded: Not a study.5018404
144 McCloskey LJ, Bordash FR, Ubben KJ, . Decreasing the cutoff for elevated blood lead (EBL) can decrease the screening sensitivity for EBL. Am J Clin Pathol. 2013;139(3):360–7. doi: 10.1309/AJCP5RKWF3IZTCTO. PMID: 23429373. Excluded: Wrong study design for Key Question.23429373
145 McKay CA, Jr. Role of chelation in the treatment of lead poisoning: discussion of the Treatment of Lead-Exposed Children Trial (TLC). J Med Toxicol. 2013;9(4):339–43. doi: 10.1007/s13181-013-0341-8. PMID: 24178899. Excluded: Not a study.24178899
146 Miranda ML, Dolinoy DC, Overstreet MA. Mapping for prevention: GIS models for directing childhood lead poisoning prevention programs. Environmental Health Perspectives. 2002;110(9):947–53. PMID: 12204831. Excluded: Not a study.12204831
147 Mitchell DG, Aldous KM, Ryan FJ. Mass screening for lead poisoning: Capillary blood sampling and automated Delves-cup atomic-absorption analysis. N Y State J Med. 1974;74(9):1599–603. PMID: 4527069. Excluded: Wrong intervention.4527069
148 Montoya-Cabrera MA, Maldonado-Torres L, Velazwuez-Gutierrez L, . [Treatment of saturnism with a low dose of calcium disodium EDTA]. Arch Invest Med (Mex). 1974;5(3):603–8. PMID: 4218477. Excluded: Not English language, but possibly relevant.4218477
149 Moriarty RW. Screening to prevent lead poisoning. Pediatrics. 1974;54(5):626–8. PMID: 4453465. Excluded: Not a study.4453465
150 Ness R. Practice guidelines for childhood lead screening in primary care. J Pediatr Health Care. 2013;27(5):395–9. doi: 10.1016/j.pedhc.2012.12.013. PMID: 23465780. Excluded: Not a study.23465780
151 Newton WP. Screening for lead poisoning in a suburban practice. J Fam Pract. 1995;41(1):95–6. PMID: 7798071. Excluded: Not a study.7798071
152 Nicholson JS, Cleeton M. Validation and assessment of pediatric lead screener questions for primary prevention of lead exposure. Clin Pediatr. 2016;55(2):129–36. doi: 10.1177/0009922815584944. PMID: 25986443. Excluded: Wrong comparator.25986443
153 Nordin JD, Rolnick SJ, Griffin JM. Prevalence of excess lead absorption and associated risk factors in children enrolled in a midwestern health maintenance organization. Pediatrics. 1994;93(2):172–7. PMID: 8121726. Excluded: Wrong comparator.8121726
154 Nussbaumer-Streit B, Yeoh B, Griebler U, . Household interventions for preventing domestic lead exposure in children. Cochrane Database Syst Rev. 2016 (10). Excluded: Wrong intervention.
155 O’Donohoe NV. Lead poisoning in childhood treated by the subcutaneous administration of a chelating agent. Arch Dis Child. 1956;31(158):321–3. PMID: 13363476. Excluded: Not a study.13363476
156 Orava S, Brogan GX, Jr., Mofenson H, . Evaluation of two strategies for complying with state-mandated lead screening in the emergency department. Naussau-Suffolk Lead Committee, Naussau-Suffolk Lead Center. Acad Emerg Med. 1999;6(8):849–51. PMID: 10463559. Excluded: Wrong study design for Key Question.10463559
157 Ossiander EM. A systematic review of screening questionnaires for childhood lead poisoning. J Public Health Manag Pract. 2013;19(1):E21–9. doi: 10.1097/PHH.0b013e3182249523. PMID: 22668673. Excluded: Systematic review or meta-analysis used as a source document only to identify individual studies.22668673
158 Paulozzi LJ, Shapp J, Drawbaugh RE, . Prevalence of lead poisoning among two-year-old children in Vermont. Pediatrics. 1995;96(1 Pt 1):78–81. PMID: 7596728. Excluded: Wrong comparator.7596728
159 Pawel MA, Frantz CN, Pisetsky IB. Screening for lead poisoning with the urinary ALA test. HSMHA Health Rep. 1971;86(11):1030–6. PMID: 5138281. Excluded: Wrong study design for Key Question.5138281
160 Polivka BJ, Salsberry P, Casavant MJ, . Comparison of parental report of blood lead testing in children enrolled in Medicaid with Medicaid claims data and blood lead surveillance reports. J Community Health. 2006;31(1):43–55. PMID: 16482765. Excluded: Wrong intervention.16482765
161 Prashant V, Prashant A, Devanand D, . Screening of school children for blood lead levels and attempts to reduce them by nonpharmacological means in a coastal city of India. Indian J Med Sci. 2008;62(5):185–92. PMID: 18579977. Excluded: Wrong population.18579977
162 Pueschel SM, Kopito L, Schwachman H. Children with an increased lead burden. A screening and follow-up study. JAMA. 1972;222(4):462–6. PMID: 4677833. Excluded: Wrong study design for Key Question.4677833
163 Rainey PM, Schonfeld DJ. Comparability of capillary and venous blood samples for lead screening. JAMA. 1994;272(19):1482. PMID: 7966831. Excluded: Not a study.7966831
164 Ranmuthugala G, Karr M, Mira M, . Opportunistic sampling from early childhood centres: a substitute for random sampling to determine lead and iron status of pre-school children? Aust N Z J Public Health. 1998;22(4):512–4. PMID: 9659783. Excluded: Wrong comparator.9659783
165 Rastogi S, Nandlike K, Fenster W. Elevated blood lead levels in pregnant women: identification of a high-risk population and interventions. J Perinat Med. 2007;35(6):492–6. doi: 10.1515/JPM.2007.131. PMID: 18052836. Excluded: Wrong study design for Key Question.18052836
166 Raymond J, Wheeler W, Brown MJ, . Lead screening and prevalence of blood lead levels in children aged 1-2 years-Child Blood Lead Surveillance System, United States, 2002-2010 and National Health and Nutrition Examination Survey, United States, 1999-2010. MMWR Suppl. 2014;63(2):36–42. PMID: 25208256. Excluded: Wrong study design for Key Question.25208256
167 Reuben A, Caspi A, Belsky D, . Association of childhood blood levels with cognitive function and socioeconomic status at age 38 years and with IQ change and socioeconomic mobility between childhood and adulthood. JAMA. 2017;317(12):1244–51. PMID: 28350927. Excluded: Wrong population.28350927
168 Roberts JR, Hulsey TC, Curtis GB, . Using geographic information systems to assess risk for elevated blood lead levels in children. Public Health Rep. 2003;118(3):221–9. PMID: 12766217. Excluded: Wrong study design for Key Question.12766217
169 Rolnick SJ, Nordin J, Cherney LM. A comparison of costs of universal versus targeted lead screening for young children. Environ Res. 1999;80(1):84–91. doi: 10.1006/enrs.1998.3879. PMID: 9931230. Excluded: Wrong comparator.9931230
170 Rooney BL, Hayes EB, Allen BK, . Development of a screening tool for prediction of children at risk for lead exposure in a midwestern clinical setting. Pediatrics. 1994;93(2):183–7. PMID: 8121728. Excluded: Wrong comparator.8121728
171 Ruff HA, Bijur PE, Markowitz M, . Declining blood lead levels and cognitive changes in moderately lead-poisoned children. JAMA. 1993;269(13):1641–6. PMID: 8455297. Excluded: Wrong outcome.8455297
172 Sachs HK. Effect of a screening program on changing patterns of lead poisoning. Environ Health Perspect. 1974;7:41–5. PMID: 4831147. Excluded: Wrong study design for Key Question.4831147
173 Sargent JD, Dalton M, Klein RZ. Diagnostic testing unwarranted for children with blood lead 10 to 14 microg/dL. Pediatrics. 1999;103(4):e51. PMID: 10103343. Excluded: Wrong study design for Key Question.10103343
174 Sathyanarayana S, Beaudet N, Omri K, . Predicting children’s blood lead levels from exposure to school drinking water in Seattle, Washington, USA. Ambul Pediatr. 2006;6(5):288–92. doi: 10.1016/j.ambp.2006.07.001. PMID: 17000419. Excluded: Wrong study design for Key Question.17000419
175 Schaffer SJ, Szilagyi PG, Weitzman M. Lead poisoning risk determination in an urban population through the use of a standardized questionnaire. Pediatrics. 1994;93(2):159–63. PMID: 8121724. Excluded: Wrong comparator.8121724
176 Schell LM, Denham M, Stark AD, . Relationship between blood lead concentration and dietary intakes of infants from 3 to 12 months of age. Environ Res. 2004;96(3):264–73. doi: 10.1016/j.envres.2004.02.008. PMID: 15364593. Exclusion: 2/15364593
177 Schlenker TL, Baxmann R, McAvoy P, . Primary prevention of childhood lead poisoning through community outreach. WMJ. 2001;100(8):48–54. PMID: 12685297. Excluded: Wrong intervention.12685297
178 Schlenker TL, Fritz CJ, Murphy A, . Feasibility and effectiveness of screening for childhood lead poisoning in private medical practice. Arch Pediatr Adolesc Med. 1994;148(7):761–4. PMID: 8019635. Excluded: Wrong outcome.8019635
179 Schneider J, Aurori B, Armenti L, . Impact of community screening on diagnosis, treatment, and medical findings of lead poisoning in children. Public Health Rep. 1981;96(2):143–9. PMID: 7208798. Excluded: Wrong outcome.7208798
180 Schonfeld DJ, Cullen MR, Rainey PM, . Screening for lead poisoning in an urban pediatric clinic using samples obtained by fingerstick. Pediatrics. 1994;94(2 Pt 1):174–9. PMID: 8036069. Excluded: Wrong study design for Key Question.8036069
181 Schonfeld DJ, Rainey PM, Cullen MR, . Screening for lead poisoning by fingerstick in suburban pediatric practices. Arch Pediatr Adolesc Med. 1995;149(4):447–50. PMID: 7704175. Excluded: Wrong study design for Key Question.7704175
182 Shannon MW, Townsend MK. Adverse effects of reduced-dose d-penicillamine in children with mild-to-moderate lead poisoning. Ann Pharmacother. 2000;34(1):15–8. PMID: 10669180. Excluded: Wrong comparator.10669180
183 Shao L, Zhang L, Zhen Z. Interrupted time series analysis of children’s blood lead levels: A case study of lead hazard control program in Syracuse, New York. PLoS ONE. 2017;12(2):e0171778. doi: 10.1371/journal.pone.0171778. PMID: 28182688. Excluded: Wrong study design for Key Question.28182688
184 Sinclair DF, Dohnt BR. Sampling and analysis techniques used in a blood lead survey of 1241 children in Port Pirie, South Australia. Clin Chem. 1984;30(10):1616–9. PMID: 6478591. Excluded: Wrong intervention.6478591
185 Smith HD. Lead poisoning in children and its therapy with EDTA. Ind Med Surg. 1959;28(3):148–51; discussion 51-5. PMID: 13630577. Excluded: Not a study.13630577
186 Smith HD, King LR, Margolin EG. Treatment of lead encephalopathy. The combined use of edetate and hemodialysis. Am J Dis Child. 1965;109:322–4. PMID: 14261012. Excluded: Wrong population.14261012
187 Specter MJ, Guinee VF, Davidow B. The unsuitability of random urinary delta aminolevulinic acid samples as a screening test for lead poisoning. J Pediatr. 1971;79(5):799–804. PMID: 5116703. Excluded: Wrong outcome.5116703
188 Stark AD, Quah RF, Meigs JW, . Relationship of sociodemographic factors to blood lead concentrations in New Haven children. J Epidemiol Community Health. 1982;36(2):133–9. PMID: 7119656. Excluded: Wrong study design for Key Question.7119656
189 Stefanak MA, Bourguet CC, Benzies-Styka T. Use of the Centers for Disease Control and Prevention childhood lead poisoning risk questionnaire to predict blood lead elevations in pregnant women. Obstet Gynecol. 1996;87(2):209–12. doi: 10.1016/0029-7844(95)00397-5. PMID: 8559525. Excluded: Wrong population.8559525
190 Striph KB. Prevalence of lead poisoning in a suburban practice. J Fam Pract. 1995;41(1):65–71. PMID: 7798067. Excluded: Wrong comparator.7798067
191 Swindell SL, Charney E, Brown MJ, . Home abatement and blood lead changes in children with class III lead poisoning. Clin Pediatr (Phila). 1994;33(9):536–41. doi: 10.1177/000992289403300905. PMID: 8001322. Excluded: Wrong comparator.8001322
192 Thurtle N, Greig J, Cooney L, . Description of 3,180 courses of chelation with dimercaptosuccinic acid in children < 5 y with severe lead poisoning in Zamfara, Northern Nigeria: a retrospective analysis of programme data. PLoS Medicine. 2014;11(10):e1001739. doi: 10.1371/journal.pmed.1001739. PMID: 25291378. Excluded: Wrong population.25291378
193 Tressou J, Crepet A, Bertail P, . Probabilistic exposure assessment to food chemicals based on extreme value theory. Application to heavy metals from fish and sea products. Food Chem Toxicol. 2004;42(8):1349–58. doi: 10.1016/j.fct.2004.03.016. PMID: 15207386. Excluded: Wrong study design for Key Question.15207386
194 Triantafyllidou S, Gallagher D, Edwards M. Assessing risk with increasingly stringent public health goals: the case of water lead and blood lead in children. J Water Health. 2014;12(1):57–68. doi: 10.2166/wh.2013.067. PMID: 24642433. Excluded: Wrong study design for Key Question.24642433
195 Triantafyllidou S, Le T, Gallagher D, . Reduced risk estimations after remediation of lead (Pb) in drinking water at two US school districts. Sci Total Environ. 2014;466-467:1011–21. doi: 10.1016/j.scitotenv.2013.07.111. PMID: 23988746. Excluded: Wrong outcome.23988746
196 Verebey K. Filter paper-collected blood lead testing in children. Clin Chem. 2000;46(7):1024–8. PMID: 10894859. Excluded: Not a study.10894859
197 Verebey K, Rosen JF, Schonfeld DJ, . Blood collection and analytical considerations in blood lead screening in children. Clin Chem. 1995;41(3):469–70. PMID: 7882527. Excluded: Not a study.7882527
198 Veyhe AS, Hofoss D, Hansen S, . The Northern Norway Mother-and-Child Contaminant Cohort (MISA) Study: PCA analyses of environmental contaminants in maternal sera and dietary intake in early pregnancy. Int J Hyg Environ Health. 2015;218(2):254–64. doi: 10.1016/j.ijheh.2014.12.001. PMID: 25556042. Excluded: Wrong study design for Key Question.25556042
199 Vitale LF, Rosalinas-Bailon A, Folland D, . Oral penicillamine therapy for chronic lead poisoning in children. J Pediatr. 1973;83(6):1041–5. PMID: 4757518. Excluded: Wrong comparator.4757518
200 Wang ST, Pizzolato S, Peter F. Microsampling technique and determination of blood lead by Zeeman atomic absorption spectrophotometry. Sci Total Environ. 1988;71(1):37–43. PMID: 3358115. Excluded: Wrong outcome.3358115
201 Wasserman LR. The effects of a family-based educational intervention on the prevention of lead poisoning in children (EdD). 2002. Excluded: Wrong study design for Key Question.
202 Watt GC, Britton A, Gilmour WH, . Is lead in tap water still a public health problem? An observational study in Glasgow. BMJ. 1996;313(7063):979–81. PMID: 8892418. Excluded: Wrong study design for Key Question.8892418
203 Wei Z, Markowitz M, clement I. Therapeutic effectiveness of calcium supplementation on moderate lead poisoning in children: a double-blind randomized clinical trial. Zhonghua Er Ke Za Zhi. 1998;36(3):146–8. Excluded: Not English language, but possibly relevant.
204 Willis FR, Rossi E, Bulsara M, . The Fremantle lead study. J Paediatr Child Health. 1995;31(4):326–31. PMID: 7576892. Excluded: Wrong study design for Key Question.7576892
205 Yiin LM, Lioy PJ, Rhoads GG. Impact of home carpets on childhood lead intervention study. Environ Res. 2003;92(2):161–5. PMID: 12854696. Excluded: Wrong comparator.12854696
206 Zabel EW, Falken MC, Sonnabend M, . Prevalence of elevated blood lead levels and evaluation of a lead-risk-screening questionnaire in rural Minnesota. J Environ Health. 2005;68(2):9–15, 36. PMID: 16220717. Excluded: Wrong comparator.16220717
207 Zheng J, Huynh T, Gasparon M, . Human health risk assessment of lead from mining activities at semi-arid locations in the context of total lead exposure. Environ Sci Pollut Res Int. 2013;20(12):8404–16. doi: 10.1007/s11356-013-2145-4. PMID: 24122159. Excluded: Wrong study design for Key Question.24122159
208 Zierold KM, Havlena J, Anderson H. Exposure to lead and length of time needed to make homes lead-safe for young children. Am J Public Health. 2007;97(2):267–70. doi: 10.2105/AJPH.2005.067603. PMID: 17194869. Excluded: Wrong outcome.17194869

## Appendix A6 USPSTF Quality Rating Criteria

### Systematic Reviews

Criteria:

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

Definition of ratings based on above criteria:

- Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions
- Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies
- Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

### Case-Control Studies

Criteria:

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls, with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

Definition of ratings based on above criteria:

- Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; accurate diagnostic procedures and measurements applied equally to cases and controls; and appropriate attention to confounding variables
- Fair: Recent, relevant, and without major apparent selection or diagnostic workup bias, but response rate less than 80 percent or attention to some but not all important confounding variables
- Poor: Major selection or diagnostic workup bias, response rate less than 50 percent, or inattention to confounding variables

### RCTs and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  - For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  - For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Definition of ratings based on above criteria:

- Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
- Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
- Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria:

- Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease
- Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients
- Poor: Has a fatal flaw, such as: Uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

*Reference: U.S. Preventive Services Task Force Procedure Manual. July 2017. Accessed at https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes

## Appendix A7 Expert Reviewers of the Draft Report

✥ Jennifer A. Lowry, MD, Chief, Section of Toxicology and Environmental Health, Children’s Mercy
✥ Suril Mehta, MPH, Health Scientist, Office of the Report on Carcinogens, U.S. National Toxicology Program, National Institute of Environmental Health Sciences
✥ Matthew Strickland, PhD, MPH, Associate Professor of Epidemiology, School of University Health Sciences, University of Nevada, Reno
✥ Federal Partners from the United States Environmental Protection Agency
  ○ Ruth A. Etzel, MD, PhD, Director, Office of Children’s Health Protection, United States Environmental Protection Agency
✥ Additional Federal Partners from the Centers for Disease Control and Prevention
  ○ Brandy Peaker, MD, MPH, CDC Liason, Centers for Disease Control and Prevention

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings.