# References

1 Moore DL, MacDonald NE. Preventing ophthalmia neonatorum. Paediatr Child Health. 2015;20(2):93–6. PMID: 25838784. http://dx.doi.org/10.1093/pch/20.2.93 25838784
2 Workowski KA, Bolan GA, Centers for Disease Control and Prevention. Sexually transmitted diseases treatment guidelines, 2015. MMWR Recomm Rep. 64(RR-03): 1–137. PMID: 26042815.26042815
3 Kapoor V, Whyte R, Vedula S. Interventions for preventing ophthalmia neonatorum. Cochrane Database of Systematic Reviews 2016(9): Art. No.: CD001862. http://dx.doi.org/10.1002/14651858.CD001862.pub3
4 Laga M, Meheus A, Piot P. Epidemiology and control of gonococcal ophthalmia neonatorum. Bulletin of the World Health Organization. 1989;67(5):471–7. PMID: 2611972.2611972
5 Williams CL, Harrison LL, Llata E, . Sexually Transmitted Diseases Among Pregnant Women: 5 States, United States, 2009–2011. Matern Child Health J. 2018;22(4):538–45. PMID: 29417361. http://dx.doi.org/10.1007/s10995-017-2422-9 29417361
6 Wheeler R, Earnshaw VA, Kershaw T, . Postpartum sexually transmitted disease: refining our understanding of the population at risk. Sex Transm Dis. 2012;39(7):509–13. PMID: 22706211. http://dx.doi.org/10.1097/OLQ.0b013e31824e5167 22706211
7 Centers for Disease Control and Prevention. STDs in Women and Infants. https://www.cdc.gov/std/stats17/womenandinf.htm. Accessed October 17, 2018.
8 Dharmasena A, Hall N, Goldacre R, . Time trends in ophthalmia neonatorum and dacryocystitis of the newborn in England, 2000–2011: database study. Sex Transm Infect. 2015;91(5):342–5. PMID: 25512672. http://dx.doi.org/10.1136/sextrans-2014-051682 25512672
9 Pilling R, Long V, Hobson R, . Ophthalmia neonatorum: a vanishing disease or underreported notification? Eye (Lond). 2009;23(9):1879–80. PMID: 19079151. http://dx.doi.org/10.1038/eye.2008.364 19079151
10 Kreisel K, Weston E, Braxton J, . Keeping an Eye on Chlamydia and Gonorrhea Conjunctivitis in Infants in the United States, 2010–2015. Sex Transm Dis. 2017;44(6):356–8. PMID: 28499285. http://dx.doi.org/10.1097/olq.0000000000000613 28499285
11 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2017. https://www.cdc.gov/std/stats17/Gonorrhea.htm. Accessed October 17, 2018.
12 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2011. Atlanta, GA: U.S. Department of Health and Human Services: 2012.
13 U.S. Preventive Services Task Force. Ocular prophylaxis for gonococcal ophthalmia neonatorum: reaffirmation recommendation statement. Am Fam Physician. 2012;85(2):195–6; quiz 7–8. PMID: 22335221.22335221
14 Snowe RJ, Wilfert CM. Epidemic reappearance of gonococcal ophthalmia neonatorum. Pediatrics. 1973;51(1):110–4. PMID: 4734310.4734310
15 Woods CR. Gonococcal infections in neonates and young children. Semin Pediatr Infect Dis. 2005;16(4):258–70. PMID: 16210106. http://dx.doi.org/10.1053/j.spid.2005.06.006 16210106
16 Schaller UC, Klauss V. Is Crede’s prophylaxis for ophthalmia neonatorum still valid? Bulletin of the World Health Organization. 2001;79(3):262–3.11285676
17 Stephenson S. Ophthalmia Neonatorum with Especial Reference to Its Causation and Prevention. London: George Pulman and Sons, Limited, The Ophthalmoscope Press; 1907.
18 Fransen L, Nsanze H, Klauss V, . Ophthalmia neonatorum in Nairobi, Kenya: the roles of Neisseria gonorrhoeae and Chlamydia trachomatis. The Journal of infectious diseases. 1986;153(5):862–9. PMID: 3084664.3084664
19 LeFevre ML, Force USPST. Screening for Chlamydia and gonorrhea: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;161(12):902–10. http://dx.doi.org/10.7326/M14-1981 25243785
20 American Academy of Pediatrics, The American College of Obstetricians and Gynecologists. Guidelines for Perinatal Care. Eighth Edition ed 2017.
21 Hammerschlag MR. Chlamydial and gonococcal infections in infants and children. Clinical infectious diseases: an official publication of the Infectious Diseases Society of America. 2011;53 Suppl 3:S99–102. PMID: 22080275. http://dx.doi.org/10.1093/cid/cir699 22080275
22 Darling EK, McDonald H. A meta-analysis of the efficacy of ocular prophylactic agents used for the prevention of gonococcal and chlamydial ophthalmia neonatorum. J Midwifery Womens Health. 2010;55(4):319–27. PMID: 20630358. http://dx.doi.org/10.1016/j.jmwh.2009.09.003 20630358
23 Centers for Disease Control and Prevention. Antibiotic-Resistant Gonorrhea Basic Information. https://www.cdc.gov/std/gonorrhea/arg/basic.htm. Accessed March 2, 2018.
24 Public Health Agency of Canada, National Microbiology Laboratory. National Surveillance of Antimicrobial Susceptibilities of Neisseria gonorrhoeae - 2015. https://www.canada.ca/en/public-health/services/publications/drugs-health-products/national-surveillance-antimicrobial-susceptibilities-neisseria-gonorrhoeae-annual-summary-2015.html. Accessed June 5, 2018.
25 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2015: Gonococcal Isolate Surveillance Project (GISP) Supplement and Profiles. Atlanta: 2017.
26 Workowski KA, Berman S, Centers for Disease C, . Sexually transmitted diseases treatment guidelines, 2010. MMWR Recomm Rep. 2010;59(RR-12):1–110. PMID: 21160459.21160459
27 Clarke T, Norris T, Schiller J. Early release of selected estimates based on data from 2016 National Health Interview Survey. National Center for Health Statistics. May 2017. http://www.cdc.gov/nchs/nhis.htm. Accessed March 2, 2018.
28 Hamilton B, Martin J, Osterman M, . Births: Provisional data for 2016. Vital statistics rapid release; no 2. Hyattsville, MD: National Center for Health Statistics. June 2017. https://www.cdc.gov/nchs/data/vsrr/report002.pdf. Accessed March 2, 2018.
29 U.S. Preventive Services Task Force. Ocular Prophylaxis for Gonococcal Ophthalmia Neonatorum: U.S. Preventive Services Task Force Reaffirmation Recommendation Statement 2011.
30 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. PMID: None.
31 Patnode CD, Eder ML, Walsh ES, . The Use of Rapid Review Methods for the U.S. Preventive Services Task Force. Am J Prev Med. 2018;54(1S1):S19–S25. http://dx.doi.org/10.1016/j.amepre.2017.07.024 29254522
32 Mabry-Hernandez I, Oliverio-Hoffman R. Ocular Prophylaxis for Gonococcal Ophthalmia Neonatorum: Evidence Update for the U.S. Preventive Services Task Force Reaffirmation Recommendation Statement. Rockville, MD: Agency for Healthcare Research and Quality; 2010.
33 U.S. Preventive Services Task Force. Screening for Gonorrhea - Including Ocular Prophylaxis in Newborns. In: Guide to Clinical Preventive Services: Report of the US Preventive Services Task Force. 2nd edition. Baltimore (MD): Williams & Wilkins; 1996.
34 U.S. Preventive Services Task Force. Screening for gonorrhea: recommendation statement. Ann Fam Med. 2005;3(3):263–7. PMID: 15928231. http://dx.doi.org/10.1370/afm.337 15928231
35 Peterman TA, O’Connor K, Bradley HM, . Gonorrhea Control, United States, 1972–2015, A Narrative Review. Sex Transm Dis. 2016;43(12):725–30. PMID: 27835623. http://dx.doi.org/10.1097/OLQ.0000000000000515 27835623
36 Hammerschlag MR, Smith-Norowitz T, Kohlhoff SA. Keeping an Eye on Chlamydia and Gonorrhea Conjunctivitis in Infants in the United States, 2010–2015. Sex Transm Dis. 2017;44(9):577. PMID: 28809776. http://dx.doi.org/10.1097/olq.0000000000000678 28809776
37 Darling EK. Is mandatory neonatal eye prophylaxis ethically justified? A case study from Canada. Public Health Ethics 2011;4(2):185–91.
38 Kramer A, Behrens-Baumann W, (Eds). Prophylaxis against Ophthalmia Neonatorum. In: Antiseptic prophylaxis and therapy in ocular infections: principles, clinical practice and infection control: Karger Medical and Scientific Publishers; 2002.
39 Mellin GW, Kent MP. Ophthalmia neonatorum; is prophylaxis necessary. Pediatrics. 1958;22(5):1006–15. PMID: 13600927.13600927
40 Mulholland C, Gardiner J. Ophthalmia neonatorum prophylaxis. Canadian journal of ophthalmology Journal canadien d’ophtalmologie. 2015;50(4):328–9. PMID: 26257230. http://dx.doi.org/10.1016/j.jcjo.2015.04.014 26257230
41 Blatt AJ, Lieberman JM, Hoover DR, . Chlamydial and gonococcal testing during pregnancy in the United States. Am J Obstet Gynecol. 2012;207(1):55 e1–8. PMID: 22621817. http://dx.doi.org/10.1016/j.ajog.2012.04.027 22621817
42 Hammerschlag MR, Cummings C, Roblin PM, . Efficacy of neonatal ocular prophylaxis for the prevention of chlamydial and gonococcal conjunctivitis. N Engl J Med. 1989;320(12):769–72. PMID: 2922026. http://dx.doi.org/10.1056/NEJM198903233201204 2922026
43 Isenberg SJ, Apt L, Wood M. A controlled trial of povidone-iodine as prophylaxis against ophthalmia neonatorum. N Engl J Med. 1995;332(9):562–6. PMID: 7838190. http://dx.doi.org/10.1056/NEJM199503023320903 7838190
44 Laga M, Plummer FA, Piot P, . Prophylaxis of gonococcal and chlamydial ophthalmia neonatorum. A comparison of silver nitrate and tetracycline. N Engl J Med. 1988;318(11):653–7. http://dx.doi.org/10.1056/NEJM198803173181101 3278234
45 David M, Rumelt S, Weintraub Z. Efficacy comparison between povidone iodine 2.5% and tetracycline 1% in prevention of ophthalmia neonatorum. Ophthalmology. 2011;118(7):1454–8. PMID: 21439642. http://dx.doi.org/10.1016/j.ophtha.2010.12.003 21439642
46 Bramantyo T, Roeslani RD, Andriansjah A, . The Efficacy of 1% Chloramphenicol Eye Ointment Versus 2.5% Povidone-Iodine Ophthalmic Solution in Reducing Bacterial Colony in Newborn Conjunctivae. Asia Pac J Ophthalmol (Phila). 2015;4(3):180–3. PMID: 26065506. http://dx.doi.org/10.1097/apo.0000000000000070 26065506
47 Binenbaum G, Bruno CJ, Forbes BJ, . Periocular ulcerative dermatitis associated with gentamicin ointment prophylaxis in newborns. J Pediatr. 2010;156(2):320–1. PMID: 20105641. http://dx.doi.org/10.1016/j.jpeds.2009.11.060 20105641
48 Nathawad R, Mendez H, Ahmad A, . Severe ocular reactions after neonatal ocular prophylaxis with gentamicin ophthalmic ointment. Pediatr Infect Dis J. 2011;30(2):175–6. PMID: 20885334. http://dx.doi.org/10.1097/INF.0b013e3181f6c2e5 20885334
49 Wexelblatt SL, Greenberg JM, Nathan AT. Regional care model enables rapid response to adverse drug events. J Perinatol. 2010;30(4):300. PMID: 20351711. http://dx.doi.org/10.1038/ip.2010.17 20351711
50 Nishida H, Risemberg HM. Silver nitrate ophthalmic solution and chemical conjunctivities. Pediatrics. 1975;56(3):368–73. PMID: 808790.808790
51 Zuppa AA, D’Andrea V, Catenazzi P, . Ophthalmia neonatorum: what kind of prophylaxis? J Matern Fetal Neonatal Med. 2011;24(6):769–73. PMID: 21534852. http://dx.doi.org/10.3109/14767058.2010.531326 21534852
52 Churchward CP, Alany RG, Kirk RS, . Prevention of Ophthalmia Neonatorum Caused by Neisseria gonorrhoeae Using a Fatty Acid-Based Formulation. mBio. 2017;8(4). PMID: 28743809. http://dx.doi.org/10.1128/mBio.00534-17 28743809
53 Alexandre I, Justel M, Martinez P, . First attempt to implement ophthalmia neonatorum prophylaxis in angola: microorganisms, efficacy, and obstacles. J Ophthalmol. 2015. PMID: 25785190. http://dx.doi.org/10.1155/2015/326526 25785190
54 Ghotbi N, Mansori M, Kalantar M, . Comparison of the effect of tetracycline 1% and erythromycin 0. 5% ophthalmic ointments for prophylaxis of ophthalmia neonatorum. Scientific journal of kurdistan university of medical sciences. 2012;17(3):20–5. PMID: None.
55 World Health Organization. WHO guidelines for the treatment of Neisseria gonorrhoeae. World Health Organization. 2016.
56 Jackson M, Long S, Kimberlin D, . Red Book 2015: Report of the Committee on Infectious Diseases. Elk Grove Village, IL: American Academy of Pediatrics; 2015.
57 Busse J, Guyatt G. Tool to Assess Risk of Bias in Cohort Studies. https://distillercer.com/resources/. Accessed January 15, 2018.