# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Justin A. Mills, MD, MPH, at AHRQ; members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Mary Anne Jackson, MD; Margaret Hammerschlag, MD; Dorothy Moore, MD; and Angela Myers, MD, MPH, who provided expert review of the draft report; Bill G. Kapogiannis, MD, at the National Institutes of Health; Carmelle T. Norice-Tra, MD, PhD, at the National Institutes of Health; Brandy Peaker, MD, MPH, at the Centers for Disease Control and Prevention for providing federal partner review of the draft report; Smyth Lai, MLS, who conducted literature searches; and Katherine Essick, BS, who provided editorial assistance.