# Chapter 4 Discussion

## Summary of Evidence

Our systematic review yielded no relevant new studies since the 2010 review addressing the effectiveness or harms of GON prophylaxis (Table 5).^32^ A systematic review by Darling et al^22^ confirmed the scarcity of new evidence, concluding that there were insufficient data to estimate the clinical or comparative effectiveness of GON prophylaxis. Given the relatively low reported rates of maternal gonorrhea, these studies are underpowered. The foundational evidence for prior USPSTF recommendations largely consisted of observational studies from sub-Saharan Africa conducted 30 years ago (1987–1995) showing statistically significant and substantial reductions in GON after implementation of GON prophylaxis.^29,^ ^33,^ ^34^ While the USPSTF, Centers for Disease Control, American Academy of Pediatrics, and World Health Organization recommend universal GON prophylaxis based on this evidence (Table 3), others have questioned the current applicability of such evidence because the universal prenatal screening and treatment of STIs—including gonorrhea and chlamydia—introduced in the 1970s is considered the most effective preventive strategy and the standard of care.^35–37^ Historically, there has been some US and international observational evidence from over 30–50 years ago indicating that cessation of prophylaxis led to increases in GON incidence;^38,^ ^39^ however, there is no contemporary observational evidence to examine this trend in the era of prenatal screening and treatment. In the United States where risk-based prenatal gonorrhea screening is recommended, and ocular prophylaxis is the standard of care, the individual contribution of each method for preventing GON is unknown. A trial to evaluate the comparative effectiveness of each strategy is not feasible because of the extremely low incidence of GON.

Table 5 Snapshot of the Evidence

| Rationale for previous GON prophylaxis USPSTF recommendations^13,^ ^33,^ ^34^ and foundational evidence | Limitations of foundational evidence | New evidence findings
Benefits | Consistent evidence that topical ocular prophylactic preparations including erythromycin 0.5% ophthalmic ointment, tetracycline 1% ophthalmic ointment, or 1% silver nitrate solution are effective in preventing gonococcal ophthalmia neonatorum Strong evidence that universal administration of ocular prophylaxis has reduced incidence of gonococcal ophthalmia neonatorum in the United States | Primarily based on observational evidence from studies conducted in countries with limited applicability to the US over 20 years ago Limited evidence evaluating comparative effectiveness of prophylactic preparations that do not rely on antibiotics (i.e., povidone-iodine) | No new studies identified for clinical effectiveness Few new studies identified evaluating comparative effectiveness of prophylactic agents from countries with limited applicability to the United States. One study from Israel using 2003–2004 data found no difference in GON cases between iodine and tetracycline.
Harms | Harms not discussed | Reporting of harms is sparse and nonspecific, generally indicating the occurrence of chemical conjunctivitis, particularly with the use of silver nitrate | No new harms studies identified

In 2015, the Canadian Pediatric Society recommended against universal GON prophylaxis and instead supported enhanced prenatal screening and treatment, and proposed a more customized prevention program based on local epidemiology.^1^ It is possible that state-mandated ocular prophylaxis may be less warranted in some settings due to health care systems’ provision of more comprehensive access to prenatal care, presenting more opportunities to screen pregnant women for gonorrhea and address the infection prior to birth; such a strategy also considers maternal health directly. These guidelines have been met with controversy raising issues around the effectiveness of prenatal screening and treatment strategies, emergence of antimicrobial resistance, and effects on socially vulnerable populations.^40^ There is scant information available to estimate current adherence to prenatal gonorrhea screening recommendations in U.S. clinical practice. One laboratory study from a decade ago (2005–2008) including nearly 1.3 million pregnant women reported that less than 60 percent had been tested for gonorrhea.^41^ Furthermore, there remain pregnant women in the United States who lack adequate prenatal care. In 2016, 6.2 percent of births were to women with late or no prenatal care, with a greater proportion of these women belonging to racial and ethnic minority groups.^28^ Removal of universal prophylaxis could disproportionately affect these populations and consequences of missed cases have substantial clinical sequelae. One potential alternative for women solely presenting to care in labor could be rapid screening at hospital entry followed by intrapartum maternal treatment or immediate postpartum maternal and infant treatment; the timing of such a strategy may present logistic challenges. Alternatively, providing neonatal ocular prophylaxis in those whose mothers are at high risk for gonorrhea (e.g., no prenatal gonorrhea screening or no prenatal care, younger maternal age) could be considered.

Topical silver nitrate, erythromycin and tetracycline ointment appear to be effective for GON prophylaxis, although again conclusions about comparative effectiveness are limited by lack of power. The systematic review by Darling et al^22^ included three comparative effectiveness studies^42–44^ (N=18,280) showing no statistically significant differences in comparative effectiveness of GON prophylactic agents. These studies compared erythromycin 0.5% solution, povidone-iodine 2.5% solution, and silver nitrate 1% solution; tetracycline 1% ointment, erythromycin 0.5% ointment, and silver nitrate 1% solution; and tetracycline 1% ointment and silver nitrate 1% solution. Additionally, we identified two newer comparative effectiveness studies.^45,^ ^46^ One was an Indonesian RCT (N=60) comparing chloramphenicol 1% ointment to povidone-iodine 2.5% solution; however, no GON cases were found in either treatment group. The other was an Israeli RCT (n=410) comparing 2.5% povidone-iodine solution to tetracycline 1% ointment; no cases of GON were found. For comparative harms, one trial demonstrated a higher risk of noninfective (sterile) conjunctivitis with povidone-iodine solution compared with tetracycline ointment.^45^ Additionally, during a manufacturing shortage of erythromycin, the CDC listed gentamicin and azithromycin as alternative agents;^21^ there are published reports that gentamicin ophthalmic ointment is associated with severe ocular reactions.^47–49^ Silver nitrate is associated with chemical conjunctivitis. In a 1975 U.S. study of 1,000 newborns, 90 percent given silver nitrate had conjunctivitis 3 to 6 hours after birth, however the conjunctivitis resolved after 24 hours in all but 7 percent.^50^ In terms of selection of agents for GON prophylaxis, erythromycin is the only topical ophthalmic antibiotic currently available in the United States;^2^ silver nitrate 1% ophthalmic solution was discontinued due to rates of chemical conjunctivitis associated with its use and tetracycline ophthalmic ointment is no longer available. Povidone-iodine is not approved for this indication in the United States.

The ideal candidate agent for prophylaxis would: 1) be effective against GON with low risk for antibiotic resistance; 2) not cause chemical conjunctivitis; 3) be inexpensive in single-dose vials;^51^ 4) and be FDA approved and available in the United States. Currently, erythromycin fulfills most of these criteria, but there remain some concerns about potential antibiotic resistance.^24^ Some have postulated that because current prophylaxes for gonococcal ophthalmia neonatorum rely on antibiotic ointments, alternative treatments should be developed for continued successful prevention of the condition.^52^ Data on the incidence of chemical conjunctivitis with erythromycin agent are scarce; limited evidence suggests that the risk of chemical conjunctivitis is between 10 and 13 percent.^43,^ ^51^ While it would be ideal if this agent also was effective against the more common ophthalmia neonatorum due to Chlamydia trachomatis, none of the aforementioned agents is considered effective for the prevention of chlamydial ophthalmia.^2,^ ^42^ Furthermore, other commonly infected sites such as the lungs would not be covered with ocular prophylaxis.

## Limitations

Our review was intended to support the USPSTF reaffirmation process and thus includes only the interval evidence accrued since the last recommendation in 2011. Our review was scoped to identify evidence that could result in a change in this recommendation and therefore has some notable exclusions listed here. Studies were excluded if they were not conducted in countries listed as “high” or “very high” on the Human Development Index. One study from Angola was excluded on this basis, however, had less than 10 percent followup.^53^ Another study conducted in Iran, a “high” Human Development Index country, was excluded because the full-text article was not available in English.^54^ There are no clinical effectiveness trials in the United States, and such trials would be unethical given that erythromycin prophylaxis is considered the standard of care; additionally, the incidence of GON is too low for any such trial to be feasible.

## Conclusion

There is no new evidence since the 2011 USPSTF recommendation endorsing the clinical effectiveness of GON prophylaxis. Foundational evidence supporting the effectiveness of current practice of erythromycin is derived from observational studies performed over 20 years ago outside of the United States without prenatal gonorrhea screening practices. Nonetheless, substantial historical declines in GON incidence in the U.S. are likely the result of a combination of preventive strategies including prenatal gonorrhea screening and treatment and neonatal prophylaxis.