# Chapter 3 Results

## Literature Search

Our literature search yielded 282 unique citations. From these citations, we accepted six articles for full-text review based on titles and abstracts (Appendix B Figure 1). Our review and critical appraisal of the full-text articles resulted in no new publications for either key question. Appendix D contains a list of the six articles reviewed at full-text and their reasons for exclusion.

## Results of Included Studies

### Key Question 1 What Is the Effectiveness of Ocular Prophylaxis for the Prevention of Gonococcal Ophthalmia Neonatorum and Associated Blindness?

Our literature search and appraisal revealed no studies.

### Key Question 2 What Are the Harms of Ocular Prophylaxis for the Prevention of Gonococcal Ophthalmia Neonatorum?

Our literature search and appraisal revealed no studies.