# Chapter 2 Methods

## Scope and Purpose

The USPSTF will use this evidence update to update its 2011 A recommendation on ocular prophylaxis for gonococcal ophthalmia neonatorum.^29^ Topics that represent well-established, evidence-based standards of practice within the scope of the USPSTF and remain a USPSTF priority undergo an updating process known as “reaffirmation.”^30^ Systematic review methods for reaffirmation evidence updates are described in detail elsewhere.^31^ The aim for evidence updates supporting the reaffirmation process is to identify “new and substantial evidence sufficient enough to change the prior recommendation.”^30,^ ^31^ As such, only targeted key questions for benefits and harms of prophylaxis are updated. In consultation with members of the USPSTF, we developed an analytic framework (Figure 1) and two Key Questions (KQs) to guide our evidence update.

Figure 1 Analytic Framework

Figure 1 is the analytic framework that depicts the two Key Questions to be addressed in the systematic review. The figure illustrates how ocular prophylaxis for the prevention of gonococcal ophthalmia neonatorum may result in improved health outcomes, including reduced gonococcal ophthalmia neonatorum and associated blindness (Key Question 1). Additionally, the figure illustrates whether ocular prophylaxis for gonococcal ophthalmia neonatorum is associated with any harms (Key Question 2).

1. What is the effectiveness of ocular prophylaxis for the prevention of gonococcal ophthalmia neonatorum and associated blindness?
2. What are the harms of ocular prophylaxis for the prevention of gonococcal ophthalmia neonatorum?

## Data Sources and Searches

We conducted a literature search of PubMed and the Cochrane Central Register of Controlled Trials (CENTRAL) from January 1, 2008, to January 16, 2018. We worked with a research librarian to develop our search strategy, which was peer-reviewed by a second research librarian (Appendix A). We limited our searches to articles published in English. We managed literature search results using EndNote® version X7 (Thomson Reuters, New York, NY).

## Study Selection

We developed specific inclusion criteria to guide study selection (Appendix A Table 1). Two reviewers independently reviewed the title and abstracts of all identified articles using DistillerSR (Evidence Partners, Ottawa, Canada). Two reviewers then independently evaluated the full text of all potentially relevant articles. We resolved differences in abstract or full-text review by discussion. For all KQs, studies conducted in any birth setting in countries categorized as “high” or “very high” on the Human Development Index (HDI) were eligible. Consistent with the methods of the USPSTF,^30^ restrictions based on “high” or “very high” HDI were made to ensure applicability to the United States. Editorials, narrative reviews, and case reports were excluded.

For evidence on the effectiveness of ocular prophylaxis for the prevention of gonococcal ophthalmia neonatorum (KQ1), we included randomized controlled trials, systematic reviews, and meta-analyses. For evidence on the harms of ocular prophylaxis for the prevention of gonococcal ophthalmia neonatorum (KQ2), we additionally allowed cohort studies, case-control studies and large case series of 100 or greater. Ocular prophylaxis needed to be conducted in newborns, but no restrictions were made for timing of administration or agents used.

## Quality Assessment and Data Abstraction and Synthesis

Two reviewers independently assessed the methodological quality of each included study using predefined criteria (Appendix A Table 2); disagreements were resolved by discussion. There were no studies eligible for inclusion, thus, no data abstraction or synthesis were performed.

## Expert Review and Public Comment

A draft Research Plan for this review was available for public comment from December 7, 2017, to January 10, 2018. The draft Research Plan was additionally reviewed by USPSTF Federal Partners from the CDC and clarifications were made as appropriate. The draft version of this report was reviewed by four invited experts and three USPSTF Federal Partners. Experts were selected based on their expertise in pediatric infectious disease. All expert comments were considered. Additional historical and epidemiological background information was added to the Introduction and themes in the Discussion were extended based on expert feedback. Additionally, a draft of the full report was posted on the USPSTF Web site from September 11, 2018 to October 9, 2018. Updated epidemiologic data that were published by the CDC during the public comment period were incorporated into the Final Report and minor clarifying revisions were made in the Introduction.

## USPSTF Involvement

This reaffirmation evidence update was funded by an AHRQ contract to support the USPSTF. We consulted with USPSTF members during the development of the research plan, including the analytic framework, KQs, and inclusion criteria. An AHRQ Medical Officer provided project oversight, reviewed the draft and final versions of the evidence update, and assisted with public comment on the research plan and draft report. The USPSTF and AHRQ had no role in the study selection, quality assessment, or writing of the evidence update.