# Chapter 1 Introduction

## Condition Background

### Condition Definition

Ophthalmia neonatorum is conjunctivitis in infants during the first month of life. Ophthalmia neonatorum can be caused by infection with Neisseria gonorrhoeae (N. gonorrhoeae), Chlamydia trachomatis (C. trachomatis), or other bacteria or viruses.^1^ This report specifically evaluates ocular prophylaxis for gonococcal ophthalmia neonatorum (GON), which occurs when gonococcal infection is transmitted to newborns during delivery by mothers infected with N. gonorrhoeae.^2^ Ophthalmia neonatorum is caused far less often by N. gonorrhoeae than by other bacteria or viruses and is rare in the United States; however, prevention is important because GON is associated with a high risk of corneal perforation and blindness which can occur within 24 hours.^3^

### Disease Incidence and Burden of Disease

The rates of gonococcal conjunctivitis in infants are determined by the rates of gonorrhea among women of reproductive age (Table 1). Robust estimates of gonorrhea in pregnant women in the United States primary care setting are not available, but older data from the World Health Organization (WHO) suggest that rates of gonorrhea in pregnant women in most industrialized countries is less than 1 percent;^4^ self-reported data from the United States Pregnancy Risk Assessment Monitoring System from 5 states from 2009–2011 suggests a similar rate of 0.5 percent.^5,^ ^6^ The rate of GON has remained low in the United States in recent years. When defined as gonorrhea in infants less than 1 year with a specimen source of “eye” or “conjunctiva,” there were an estimated 0.4 cases or fewer per 100,000 live births per year during 2013–2017.^7^ However, limitations in reporting suggest this is an underestimate;^8–10^ nearly 85 percent of combined chlamydial and gonococcal cases in infants less than 1 year do not report the specimen source so are not counted among cases.^10^ With a broader definition including cases with unknown, other, or missing specimen sources, the prevalence of GON was possibly as high as 1.1 to 1.6 cases per 100,000 live births from 2010–2015. Additionally, while GON is defined as gonococcal conjunctivitis in infants age 1 month or less, national reporting of cases is for age 1 or less, meaning that precise estimates of GON rates are not available. Of the combined chlamydial and gonococcal conjunctivitis cases reported from 2010–2015 with age 1 year or less, 36.2 percent were among Non-Hispanic black infants, followed by those reporting “other” or “unknown” race (32.0%), non-Hispanic whites (20.1%), and Hispanics (11.7%).^10^

Table 1 Rates of Reported Gonorrhea Cases per 100,000 Women of Childbearing Age by Race/Ethnicity and Age Group, United States, 2017^11^

Age | White | Black | Asian | Native Hawaiian/Other Pacific Islander | American Indian/Alaska Native | Hispanic | Overall
15–19^*^ | 197.5 | 1,843.8 | 52.3 | 498.0 | 806.0 | 247.6 | 557.4
20–24 | 280.0 | 2,066.8 | 71.9 | 769.7 | 1,232.2 | 339.6 | 648.8
25–29 | 205.8 | 1,104.4 | 37.8 | 392.7 | 1,164.9 | 229.0 | 413.7
30–34 | 134.6 | 489.9 | 26.7 | 230.0 | 819.1 | 131.5 | 223.3
35–39 | 81.4 | 245.2 | 18.0 | 225.7 | 446.3 | 81.5 | 129.3
40–44 | 40.6 | 106.0 | 10.4 | 86.4 | 298.7 | 37.6 | 63.8
All Ages | 58.5 | 444.3 | 16.7 | 177.3 | 363.6 | 87.5 | 141.8

* Reported cases of gonorrhea in women are largest at age 19, with 872.2 cases per 100,000.

The incidence of gonorrhea varies widely by age, race and ethnicity, geography, and sex. Adolescents and young adult women have the highest rates of gonorrhea, with incidence peaking at age 19 (872.2 cases per 100,000 women); among women 20–24 years of age, there were 684.8 reported cases per 100,000 women in 2017.^11^ The racial and ethnic distribution of neonatal conjunctivitis cases in infants generally corresponds with that of incident gonorrhea in women of childbearing age. In 2017, the rate of gonorrhea in black women was 7.6 times the rate in white women (444.3 vs. 58.5 cases per 100,000 women) (Table 1).^11^ Rates of gonorrhea in women are highest in the South (194.0 cases per 100,000 women vs. 129.6 in the Northeast, 169.0 in the West, and 170.6in the Midwest) (Table 2). Rates of reported gonorrhea are higher in men than in women (202.5vs. 141.8 cases per 100,000 population).^11^ Although rates of reported gonococcal infections have declined since national screening programs for women were implemented in the 1970s, there has been a recent increase in rates of reported gonorrhea cases, from 105.3 cases per 100,000 population in 2013 to 171.9 cases per 100,000 population in 2017.^11^

Table 2 Rates of Reported Gonorrhea per 100,000 Women by Region, United States, 2017^11^

Northeast | Midwest | South | West | Overall
84.5 | 157.9 | 172.7 | 120.1 | 141.8

Infants of mothers at increased risk for sexually transmitted infections are more likely to develop gonococcal conjunctivitis. Risk factors for gonorrhea among women of childbearing age include living in a high-morbidity area, previous or coexisting sexually transmitted infection(s), new or multiple sexual partners, inconsistent condom use among persons not in mutually monogamous relationships, and exchanging sex for money or drugs. A high proportion of pregnant women with gonococcal infections are asymptomatic; it is estimated that 80 percent of gonococcal infections in women are asymptomatic.^12^

In the absence of ocular prophylaxis, studies have estimated transmission rates of 30 to 50 percent from mother to newborn.^4^ Untreated gonococcal ophthalmia neonatorum can result in corneal scarring, ocular perforation, and blindness as early as 24 hours after birth.^13–15^ There are no published contemporary estimates of GON-related blindness in the US; it is considered rare in industrialized countries.^16^ Even historical information about GON-related blindness is limited. In the late 19^th^ century, prior to Crede’s prophylaxis with silver nitrate, ophthalmia neonatorum, primarily caused by gonorrhea, was considered a major cause of childhood blindness; in Europe at that time, the prevalence of ophthalmia neonatorum among live births in maternity hospitals was greater than 10 percent, resulting in corneal damage in 20 percent and blindness in approximately 3 percent of these infected infants.^16,^ ^17^ An observational study from Nairobi, Kenya in the 1980s reported that 16 percent of a series of 64 infants with GON had corneal involvement.^18^

### Prevention

Gonococcal ophthalmia neonatorum may be most effectively prevented by screening and treating gonococcal infections in pregnant women, as well as by administering ocular prophylaxis. Risk-based prenatal gonorrhea screening is widely recommended in the US as screening tests are highly accurate and effective treatments are available.^2,^ ^19,^ ^20^ Neonatal ocular prophylaxis is mandated in most states and is considered most effective when administered up to 1 hour after birth. Erythromycin ophthalmic ointment is currently the only FDA-approved prophylactic agent available in the United States.^21^ There are reports of failures of ocular prophylaxis to prevent GON and it has been postulated that reasons for these failures can include poor compliance with protocols, reinfection from other portals of entry such as the oropharynx, or contact spread.^22^ It is unknown whether antimicrobial resistance may also reduce the efficacy of prophylaxis. Other preparations, such as tetracycline ophthalmic ointment and silver nitrate, have been evaluated but are no longer available in the United States. There are reports that gentamicin was used during a period where there was an erythromycin shortage but resulted in ocular reactions.^21^

The growing threat of antimicrobial resistance may constrain successful treatment of gonorrhea. The bacterium responsible for gonorrhea, N. gonorrhoeae, has developed resistance to the majority of antibiotics used to treat gonorrhea in adults, including sulfonamides, penicillin, tetracycline, and fluoroquinolones, such as ciprofloxacin.^23^ There are reports from other countries of high N. gonorrhoeae resistance to erythromycin (32.4%), but these data are not for an ophthalmic ointment formulation.^24^ Resistance of N. gonorrhoeae to erythromycin is not surveilled in the United States because it is not a recommended treatment; erythromycin has not been a recommended treatment since the 1980s because of treatment failures in the United States that were reported at that time.^2^ It is unclear whether the high concentration of erythromycin in the eye during prophylaxis would overcome resistance.^1^ Gonococcal resistance to other macrolides, namely azithromycin, has increased over time and raises concerns about ongoing treatment using this agent.^25^

In addition to prevention, treatment of diagnosed GON can prevent the sequelae of infection. The CDC recommends GON treatment with a single dose of systemic ceftriaxone in those neonates diagnosed with GON as well as presumptive treatment in those neonates born to mothers with untreated gonorrhea.^2^

## Previous USPSTF Recommendation and Current Clinical Practice in the United States

The 1996 A recommendation for prophylactic ocular topical medication for all newborns for the prevention of GON was based on good evidence that blindness due to GON has become rare in the United States since the implementation of universal preventive medication of infants in addition to screening programs for women; this procedure is required by law in most states.^26^ In 2005, as part of a broad review of gonococcal screening in adults, the USPSTF reviewed an updated literature search on the harms of ocular prophylaxis and reaffirmed its A recommendation. Again in 2011, the USPSTF reaffirmed its previous recommendation, using a brief evidence update that found no substantial new evidence regarding the benefits or harms of prophylaxis for the prevention of GON.^13^

The Centers for Disease Control and Prevention, American Academy of Pediatrics, and WHO also recommend universal topical ocular prophylaxis for the prevention of gonococcal ophthalmia neonatorum (Table 3). These organizations explicitly recommend administering prophylaxis to all infants at birth. Conversely, recent recommendations from the Canadian Pediatric Society suggest that neonatal ocular prophylaxis may no longer be useful and should not be routinely recommended. Its recommendation to rescind regulations that mandate ocular prophylaxis is in line with that of several European countries, including Denmark, Norway, Sweden, and the United Kingdom, which abandoned universal prophylaxis decades ago.^1^ Estimates of GON incidence since this practice stopped are not robust,^16^ due in part to its rarity. Canada discontinued national surveillance of neonatal ophthalmia in 2000 due to low incidence.^1^

Table 3 Recommendations for Ocular Prophylaxis for Gonococcal Ophthalmia Neonatorum

Organization Year | Recommendation
American Academy of Pediatrics (AAP) and American College of Obstetricians and Gynecologists (ACOG)^20^ 2017 | Antimicrobial ophthalmic prophylaxis soon after delivery is recommended for all newborn infants but should be delayed until after the initial breastfeeding in the delivery room. A variety of topical agents appear to be equally efficacious, but only erythromycin ophthalmic ointment is currently commercially available in the US. Application of a 1-cm ribbon of sterile ophthalmic ointment containing erythromycin (0.5%) in each lower conjunctival sac is recommended. Care should be taken to ensure that the agent reaches all parts of the conjunctival sac. The eyes should not be irrigated with saline or distilled water after application of any of these agents; however, after 1 minute, excess ointment can be wiped away with sterile cotton.
World Health Organization^55^ 2016 | For all neonates, the WHO STI guideline recommends topical ocular prophylaxis for the prevention of gonococcal and chlamydial ophthalmia neonatorum. Strong recommendation, low quality evidence.
American Academy of Pediatrics^56^ 2015 | For prevention of gonococcal ophthalmia in newborn infants, 0.5% erythromycin ophthalmic ointment should be instilled in each eye in a single application.
Centers for Disease Control and Prevention^2^ 2015 | To prevent gonococcal ophthalmia neonatorum, a prophylactic agent should be instilled into both eyes of all newborn infants. Recommended regimen: Erythromycin (0.5%) ophthalmic ointment in each eye in a single application at birth
Canadian Pediatric Society^1^ 2015 | Neonatal ocular prophylaxis with erythromycin, the only agent currently available in Canada for this purpose, may no longer be useful and, therefore, should not be routinely recommended. Pediatricians and other physicians caring for newborns should advocate to rescind ocular prophylaxis regulations in jurisdictions in which this is still legally mandated. Jurisdictions in which ocular prophylaxis is still mandated should assess their current rates of neonatal ophthalmia and consider other, more effective preventive strategies.
U.S. Preventive Services Task Force^29^ 2011 | Provide prophylactic ocular topical medication for the prevention of gonococcal ophthalmia neonatorum. (A recommendation)

The prevention of GON can also be achieved by gonorrhea screening and treatment of pregnant women prior to delivery. In 2014, the USPSTF issued a B recommendation to screen pregnant women age 24 years and younger and in older women at increased risk of infection (Table 4).^19^

Table 4 Recommendations for Prenatal Gonorrhea Screening and Treatment

Organization Year | Recommendation
U.S. Preventive Services Task Force^29^ 2011 | Screen pregnant women age 24 years and younger and in older women at increased risk of infection (B recommendation)
American Academy of Pediatrics (AAP) and American College of Obstetricians and Gynecologists (ACOG)^20^ 2017 | Screen all pregnant women at increased risk for gonorrhea or living in an area with high prevalence at the first prenatal visit; - If negative but high risk, retest at 3^rd^ trimester; - If positive, retest in 3 to 6 months, preferably in the 3^rd^ trimester
Canadian Pediatric Society^1^ 2015 | Screen all pregnant women at the first prenatal visit; - If negative but high risk, retest at 3^rd^ trimester; - If positive, treat and retest to ensure therapeutic success; retest in 3^rd^ trimester, failing that, retest at delivery; Pregnant women not screened during pregnancy should be screened at delivery

The 2017 joint recommendation from the American Academy of Pediatrics (AAP) and American College of Obstetricians and Gynecologists (ACOG) is similar, calling for screening of all pregnant women at risk for gonorrhea or living in an area with high prevalence at the first prenatal visit, where those with gonococcal infection are retested in 3 to 6 months, preferably in the third trimester.^20^ In addition, if the first test is negative, but the woman is at high risk for gonorrhea, a retest at the beginning of the third trimester is recommended. While Canadian recommendations no longer recommend ocular prophylaxis for GON, they call for increased gonorrhea screening, to include screening all pregnant women at the first prenatal visit.^1^

Despite recent health care reforms in the United States, approximately 11.8 percent of women ages 18–24 and 14.6 percent of women ages 25–34 years were still without health insurance in 2016.^27^ Likewise, in 2016, an estimated 6.2 percent of births in the United States occurred in women who received little to no prenatal care.^28^ The percent of women receiving late or no prenatal care varies widely by race and ethnicity; it is lowest among White women (4.3%) and highest among Native Hawaiian or Pacific Islanders (19.2%). Thus, while prenatal screening and treatment of maternal gonorrhea are considered the most effective preventive strategy for neonatal gonococcal ophthalmia neonatorum, universal neonatal ocular prophylaxis remains the standard of care in the United States.