# Appendix D List of Excluded Studies

Reason for Exclusion
E1 | Study relevance
E2 | Setting: Not in “high” or “very high” Human Development Index country
E3 | Population: Not newborns
E4 | Outcome: No relevant outcomes
E5 | Intervention: Not ocular prophylaxis for gonococcal ophthalmia neonatorum
E6 | Publication type/study design
E7 | Study quality
E8 | Publication not available in English

1. Ghaemi S, Navaei P, Rahimirad S, . Evaluation of preventive effects of colostrum against neonatal conjunctivitis: A randomized clinical trial. J Educ Health Promot. 2014;3:63. PMID: 25077156. KQ1E4, KQ2E4.25077156
2. Nathawad R, Mendez H, Ahmad A, . Severe ocular reactions after neonatal ocular prophylaxis with gentamicin ophthalmic ointment. Pediatr Infect Dis J. 2011;30(2):175–6. PMID: 20885334. KQ1E4, KQ2E7.20885334
3. Scott WJ, Eck CD. Povidone-iodine and ophthalmia neonatorum. Ophthalmology. 2012;119(3):653–4; author reply 4. PMID: 22385492. KQ1E6, KQ2E6.22385492
4. Wexelblatt SL, Greenberg JM, Nathan AT. Regional care model enables rapid response to adverse drug events. J Perinatol. 2010;30(4):300. PMID: 20351711. KQ1E6, KQ2E6.20351711
5. Silva LR, Gurgel RQ, Lima DR, . Current usefulness of Crede’s method of preventing neonatal ophthalmia. Ann Trop Paediatr. 2008;28(1):45–8. PMID: 18318948. KQ1E7, KQ2E1.18318948
6. Ghotbi N, Mansori M, Kalantar M, . Comparison of the effect of tetracycline 1% and erythromycin 0.5% ophthalmic ointments for prophylaxis of ophthalmia neonatorum. Scientific Journal of Kurdistan University of Medical Sciences. 2012;17(3):20–5. PMID: None. KQ1E8, KQ2E8