# Appendix C List of Included Studies

No studies were included for KQ1 or KQ2.