# Appendix B Figure 1 Literature Flow Diagram

Appendix B Figure 1 displays the literature search results and article flow for the review. A total of 282 abstracts were screened and 6 full-text articles were assessed for eligibility. No new studies were identified.