# Appendix A Detailed Methods

## Literature Search Strategies

CENTRAL

#1 | (gonorr* or chlamyd*):ti,ab,kw
#2 | conjunctiv*:ti,ab,kw
#3 | (eye or ocular):ti,ab,kw near/3 infect*:ti,ab,kw
#4 | #1 and (#2 or #3)
#5 | inclusion:ti,ab,kw near/1 (blennorrhea* or conjunctiv*):ti,ab,kw
#6 | trachoma*:ti,ab,kw
#7 | #4 or #5 or #6 968
#8 | (infan* or newborn* or (new* next born*) or neonat* or (neo next nat*)):ti,ab,kw
#9 | #7 and #8
#10 | ophthalmia:ti,ab,kw near/5 (infan* newborn* or (new* next born*) or neonat* or (neo next nat*)):ti,ab,kw
#11 | #9 or #10 Publication Year from 2008 to 2018, in Trials

PubMed

#29 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #28 AND English[Language] AND (“2008/01/01”[Date - Publication] : “3000”[Date - Publication])
#28 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #26 NOT #27
#27 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search animals[MeSH Terms] NOT (animals[MeSH Terms] AND Humans[MeSH Terms])
#26 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #23 OR #24 OR #25
#25 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ophthalmia[tiab] AND (newborn*[tiab] OR new-born*[tiab] OR “newly born”[tiab] OR neonat*[tiab] OR neo nat*[tiab])
#24 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search Ophthalmia Neonatorum[MeSH:NoExp]
#23 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #21 AND #22
#22 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Infant, Newborn”[Mesh] OR infan*[tiab] OR newborn*[tiab] OR new-born*[tiab] OR “newly born”[tiab] OR neonat*[tiab] OR neo nat*[tiab]
#21 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #16 OR #17 OR #18 OR #19 OR #20
#20 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search trachoma*[tiab
#19 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search inclusion[tiab] AND (blennorrhea*[tiab] OR conjunctiv*[tiab])
#18 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search trachoma[MeSH:NoExp]
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “conjunctivitis, inclusion”[MeSH:NoExp]
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #9 AND #15
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #10 OR #11 OR #12 OR #13 OR #14
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (eye*[tiab] OR ocular[tiab]) AND infect*[tiab]
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search conjunctiv*[tiab]
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search eye infections[Mesh:NoExp]
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “conjunctivitis, bacterial”[MeSH:NoExp]
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search conjunctivitis[Mesh:NoExp]
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search chlamyd*[tiab]
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search Chlamydia Infections[Mesh:NoExp]
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search chlamydia trachomatis[Mesh:NoExp]
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search chlamydia muridarum[MeSH:NoExp]
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search chlamydia[MeSH:NoExp]
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search gonorr*[tiab]
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search neisseria gonorrhoeae[MeSH:NoExp]
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Gonorrhea”[Mesh:NoExp]

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Included | Excluded
Populations | Newborns | Populations other than newborns
Interventions | Ocular prophylaxis for gonococcal ophthalmia neonatorum | Treatments other than ocular prophylaxis
Comparisons | KQ1: No treatment, placebo (randomized, controlled trials) KQ2: No treatment (randomized, controlled trials) or no comparator (observational studies) | Comparative effectiveness
Outcomes | KQ1: Incidence of gonococcal ophthalmia neonatorum, visual impairment, blindness KQ2: Harms of ocular prophylaxis | Cost-effectiveness or cost-related outcomes
Setting | Any birth setting | No exclusions
Country | Studies conducted in countries categorized as “high” or “very high” on the Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries categorized as less than “high” or “very high”
Study design | KQ1: Randomized, controlled trials; systematic reviews and meta-analyses KQ2: Randomized, controlled trials; systematic reviews and meta-analyses; cohort studies, case-control studies, and large case series (≥100) | Narrative reviews, editorials, and case reports
Publication language | English-language only | Languages other than English
Study quality | Fair- or good-quality studies | Poor-quality studies

Appendix A Table 2 Study Design–Specific Quality Rating Criteria

Study Design | Adapted Quality Criteria
RCT^30^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias in classifying interventions; - Participant intervention status is clearly and explicitly defined and measured; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Confounding variables that are controlled for in analysis are reasonably complete; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported
Cohort^57^ | - Was selection of exposed and non-exposed cohorts drawn from the same population?; - Can we be confident in the assessment of exposure?; - Can we be confident that the outcome of interest was not present at start of study?; - Did the study match exposed and unexposed for all variables that are associated with the outcome of interest or did the statistical analysis adjust for these prognostic variables?; - Can we be confident in the assessment of the presence or absence of prognostic factors?; - Can we be confident in the assessment of outcome?; - Was the follow up of cohorts adequate?; - Were co-Interventions similar between groups?

Abbreviations: CCT = controlled clinical trial; RCT = randomized, controlled trial