# References

1 American Psychological Association. Diagnostic and Statistical Manual for Psychiatric Disorders. 5th ed. Washington, DC: American Psychological Association; 2013.
2 Kim DR, Epperson CN, Weiss AR, . Pharmacotherapy of postpartum depression: an update. Expert Opinion on Pharmacotherapy. 2014;15(9):1223–34. 10.1517/14656566.2014.911842 24773410
3 Fitelson E, Kim S, Baker A, . Treatment of postpartum depression: clinical, psychological and pharmacological options. Int J Womens Health. 2010;3:1–14. PMID: 21339932. 10.2147/IJWH.S6938 21339932
4 Bloch M, Daly RC, Rubinow DR. Endocrine factors in the etiology of postpartum depression. Compr Psychiatry. 2003;44(3):234–46. PMID: 12764712. 10.1016/S0010-440X(03)00034-8 12764712
5 Center for Behavioral Health Statistics and Quality. Behavioral Health Trends in the United States: Results from the 2014 National Survey on Drug Use and Health. Rockville, MD: Substance Abuse and Mental Health Services Administration; 2015. Available from: https://www.samhsa.gov/data/sites/default/files/NSDUH-FRR1-2014/NSDUH-FRR1-2014.pdf.
6 Center for Behavioral Health Statistics and Quality. Results from the 2016 National Survey on Drug Use and Health: Detailed Tables. Rockville, MD: Substance Abuse and Mental Health Services Administration; 2017. Available from: https://www.samhsa.gov/data/sites/default/files/NSDUH-DetTabs-2016/NSDUH-DetTabs-2016.pdf.
7 Hoertel N, Lopez S, Peyre H, . Are symptom features of depression during pregnancy, the postpartum period and outside the peripartum period distinct? Results from a nationally representative sample using item response theory (IRT). Depress Anxiety. 2015;32(2):129–40. PMID: 25424539. 10.1002/da.22334 25424539
8 Norhayati MN, Hazlina NH, Asrenee AR, . Magnitude and risk factors for postpartum symptoms: a literature review. J Affect Disord. 2015;175:34–52. PMID: 25590764. 10.1016/j.jad.2014.12.041 25590764
9 Ko JY, Rockhill KM, Tong VT, . Trends in Postpartum Depressive Symptoms - 27 States, 2004, 2008, and 2012. MMWR Morb Mortal Wkly Rep. 2017;66(6):153–8. PMID: 28207685. 10.15585/mmwr.mm6606a1 28207685
10 Santos IS, Matijasevich A, Barros AJ, . Antenatal and postnatal maternal mood symptoms and psychiatric disorders in pre-school children from the 2004 Pelotas Birth Cohort. J Affect Disord. 2014;164:112–7. PMID: 24856563. 10.1016/j.jad.2014.04.033 24856563
11 Sit D, Luther J, Buysse D, . Suicidal ideation in depressed postpartum women: Associations with childhood trauma, sleep disturbance and anxiety. J Psychiatr Res. 2015;66–67:95–104. PMID: 26001587. 10.1016/j.jpsychires.2015.04.021 26001587
12 Jennings KD, Ross S, Popper S, . Thoughts of harming infants in depressed and nondepressed mothers. J Affect Disord. 1999;54(1–2):21–8. PMID: 10403143.10403143
13 Lovejoy MC, Graczyk PA, O’Hare E, . Maternal depression and parenting behavior: a meta-analytic review. Clin Psychol Rev. 2000;20(5):561–92. PMID: 10860167.10860167
14 Beck CT. The effects of postpartum depression on maternal-infant interaction: a meta-analysis. Nurs Res. 1995;44(5):298–304. PMID: 7567486.7567486
15 Szegda K, Markenson G, Bertone-Johnson ER, . Depression during pregnancy: a risk factor for adverse neonatal outcomes? A critical review of the literature. J Matern Fetal Neonatal Med. 2014;27(9):960–7. PMID: 24044422. 10.3109/14767058.2013.845157 24044422
16 Minkovitz CS, Strobino D, Scharfstein D, . Maternal depressive symptoms and children’s receipt of health care in the first 3 years of life. Pediatrics. 2005;115(2):306–14. PMID: 15687437. 10.1542/peds.2004-0341 15687437
17 Wouk K, Stuebe AM, Meltzer-Brody S. Postpartum Mental Health and Breastfeeding Practices: An Analysis Using the 2010–2011 Pregnancy Risk Assessment Monitoring System. Matern Child Health J. 2016;21(3):636–47. PMID: 27449655. 10.1007/s10995-016-2150-6 27449655
18 Leiferman J. The effect of maternal depressive symptomatology on maternal behaviors associated with child health. Health Educ Behav. 2002;29(5):596–607. PMID: 12238703. 10.1177/109019802237027 12238703
19 Bernazzani O, Saucier JF, David H, . Psychosocial predictors of depressive symptomatology level in postpartum women. J Affect Disord. 1997;46(1):39–49. PMID: 9387085.9387085
20 Wilson L, Reid A, Midmer D, . Antenatal psychosocial risk factors associated with adverse postpartum family outcomes. CMAJ. 1996;154(6):785–99. PMID: 8634957.8634957
21 Myers ER, Aubuchon-Endsley N, Bastian LA, . Efficacy and Safety of Screening for Postpartum Depression. Rockville MD: Agency for Healthcare Research and Quality; 2013.
22 Da Costa D, Larouche J, Dritsa M, . Psychosocial correlates of prepartum and postpartum depressed mood. J Affect Disord. 2000;59(1):31–40. PMID: 10814768.10814768
23 Beck C. Predictors of postpartum depression: an update. Nurs Res. 2001;50(5):275–85. PMID: 11570712.11570712
24 Venkatesh KK, Phipps MG, Triche EW, . The relationship between parental stress and postpartum depression among adolescent mothers enrolled in a randomized controlled prevention trial. Matern Child Health J. 2014;18(6):1532–9. PMID: 24281848. 10.1007/s10995-013-1394-7 24281848
25 Kornfeld B, Bair-Merritt M, Frosch E, . Postpartum depression and intimate partner violence in urban mothers: co-occurrence and child healthcare utilization. J Pediatr. 2012;161(2):348–53.e2. PMID: 22404952. 10.1016/j.jpeds.2012.01.047 22404952
26 Wu Q, Chen HL, Xu XJ. Violence as a risk factor for postpartum depression in mothers: a meta-analysis. Archives of Women’s Mental Health. 2012;15(2):107–14. 10.1007/s00737-011-0248-9
27 Kozhimannil K, Pereira M, Harlow B. Association between diabetes and perinatal depression among low-income mothers. JAMA. 2009;301(8):842–7. PMID: 19244191. 10.1001/jama.2009.201 19244191
28 Josefsson A, Angelsioo L, Berg G, . Obstetric, somatic, and demographic risk factors for postpartum depressive symptoms. Obstet Gynecol. 2002;99(2):223–8. PMID: 11814501.11814501
29 Kim S, Soeken T, Cromer S, . Oxytocin and postpartum depression: delivering on what’s known and what’s not. Brain Res. 2014;1580:219–32. PMID: 24239932. 10.1016/j.brainres.2013.11.009 24239932
30 Corwin E, Kohen R, Jarrett M, . The heritability of postpartum depression. Biol Res Nurs. 2010;12(1):73–83. PMID: 20453020. 10.1177/1099800410362112 20453020
31 Murphy-Eberenz K, Zandi P, March D, . Is perinatal depression familial? J Affect Disord. 2006;90(1):49–55. PMID: 16337009. 10.1016/j.jad.2005.10.006 16337009
32 Forty L, Jones L, Macgregor S, . Familiality of postpartum depression in unipolar disorder: results of a family study. Am J Psychiatry. 2006;163(9):1549–53. PMID: 16946179. 10.1176/ajp.2006.163.9.1549 16946179
33 Pinsonneault JK, Sullivan D, Sadee W, . Association study of the estrogen receptor gene ESR1 with postpartum depression--a pilot study. Arch Womens Ment Health. 2013;16(6):499–509. PMID: 23917948. 10.1007/s00737-013-0373-8 23917948
34 Couto TC, Brancaglion MY, Alvim-Soares A, . Postpartum depression: A systematic review of the genetics involved. World J Psychiatry. 2015;5(1):103–11. PMID: 25815259. 10.5498/wjp.v5.i1.103 25815259
35 Meltzer-Brody S, Stuebe A, Dole N, . Elevated corticotropin releasing hormone (CRH) during pregnancy and risk of postpartum depression (PPD). J Clin Endocrinol Metab. 2011;96(1):E40–7. PMID: 20943787. 10.1210/jc.2010-0978 20943787
36 Glynn LM, Sandman CA. Evaluation of the association between placental corticotrophin-releasing hormone and postpartum depressive symptoms. Psychosom Med. 2014;76(5):355–62. PMID: 24915294. 10.1097/psy.0000000000000066 24915294
37 O’Connor E, Rossom RC, Henninger M, . Screening for depression in adults: an updated systematic evidence review for the U.S. Preventive Services Task Force. Rockville, MD: Agency for Healthcare Research and Quality; 2016.
38 Tandon SD, Leis JA, Mendelson T, . Six-month outcomes from a randomized controlled trial to prevent perinatal depression in low-income home visiting clients. Matern Child Health J. 2014;18(4):873–81. PMID: 23793487. 10.1007/s10995-013-1313-y 23793487
39 Dennis CL. The process of developing and implementing a telephone-based peer support program for postpartum depression: evidence from two randomized controlled trials. Trials. 2014;15:131. PMID: 24742217. 10.1186/1745-6215-15-131 24742217
40 Ginsburg GS, Barlow A, Goklish N, . Postpartum Depression Prevention for Reservation-Based American Indians: Results from a Pilot Randomized Controlled Trial. Child Youth Care Forum. 2012;41(3):229–45. PMID: 22701296. 10.1007/s10566-011-9161-7 22701296
41 Phipps MG, Raker CA, Ware CF, . Randomized controlled trial to prevent postpartum depression in adolescent mothers. Am J Obstet Gynecol. 2013;208(3):192 e1–6. PMID: 23313720. 10.1016/j.ajog.2012.12.036 23313720
42 Zlotnick C, Tzilos G, Miller I, . Randomized controlled trial to prevent postpartum depression in mothers on public assistance. J Affect Disord. 2016;189:263–8. PMID: 26454186. 10.1016/j.jad.2015.09.059 26454186
43 Lavender T, Walkinshaw SA. Can midwives reduce postpartum psychological morbidity? A randomized trial. Birth. 1998;25(4):215–9. PMID: 9892887.9892887
44 Small R, Lumley J, Donohue L, . Randomised controlled trial of midwife led debriefing to reduce maternal depression after operative childbirth. BMJ. 2000;321(7268):1043–7. PMID: 11053173.11053173
45 Wisner KL, Perel JM, Peindl KS, . Prevention of postpartum depression: a pilot randomized clinical trial. Am J Psychiatry. 2004;161(7):1290–2. PMID: 15229064. 10.1176/appi.ajp.161.7.1290 15229064
46 Wisner KL, Perel JM, Peindl KS, . Prevention of recurrent postpartum depression: a randomized clinical trial. J Clin Psychiatry. 2001;62(2):82–6. PMID: 11247106.11247106
47 Lawrie TA, Hofmeyr GJ, De Jager M, . A double-blind randomised placebo controlled trial of postnatal norethisterone enanthate: the effect on postnatal depression and serum hormones. Br J Obstet Gynaecol. 1998;105(10):1082–90. PMID: 9800931.9800931
48 Harris B, Oretti R, Lazarus J, . Randomised trial of thyroxine to prevent postnatal depression in thyroid-antibody-positive women. Br J Psychiatry. 2002;180:327–30. PMID: 11925355.11925355
49 Harmon TM, Hynan MT, Tyre TE. Improved obstetric outcomes using hypnotic analgesia and skill mastery combined with childbirth education. J Consult Clin Psychol. 1990;58(5):525–30. PMID: 2254498.2254498
50 Mozurkewich EL, Clinton CM, Chilimigras JL, . The Mothers, Omega-3, and Mental Health Study: a double-blind, randomized controlled trial. Am J Obstet Gynecol. 2013;208(4):313 e1–9. PMID: 23531328. 10.1016/j.ajog.2013.01.038 23531328
51 Llorente AM, Jensen CL, Voigt RG, . Effect of maternal docosahexaenoic acid supplementation on postpartum depression and information processing. Am J Obstet Gynecol. 2003;188(5):1348–53. PMID: 12748510.12748510
52 Elliott SA, Leverton TJ, Sanjack M, . Promoting mental health after childbirth: a controlled trial of primary prevention of postnatal depression. Br J Clin Psychol. 2000;39 (Pt 3):223–41. PMID: 11033746.11033746
53 Brugha TS, Wheatley S, Taub NA, . Pragmatic randomized trial of antenatal intervention to prevent post-natal depression by reducing psychosocial risk factors. Psychol Med. 2000;30(6):1273–81. PMID: 11097068.11097068
54 Gordon RE, Gordon KK. Social factors in prevention of postpartum emotional problems. Obstet Gynecol. 1960;15:433–8. PMID: 13851228.13851228
55 Buist A, Westley D, Hill C. Antenatal prevention of postnatal depression. Arch Womens Ment Health. 1999;1:167–73.
56 Siu AL, US Preventive Services Task Force (USPSTF), Bibbins-Domingo K, . Screening for Depression in Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;315(4):380–7. PMID: 26813211. 10.1001/jama.2015.18392 26813211
57 Haran C, van Driel M, Mitchell BL, . Clinical guidelines for postpartum women and infants in primary care-a systematic review. BMC Pregnancy Childbirth. 2014;14:51. PMID: 24475888. 10.1186/1471-2393-14-51 24475888
58 Committee on Obstetric Practice. The American College of Obstetricians and Gynecologists Committee Opinion no. 630. Screening for perinatal depression. Obstet Gynecol. 2015;125(5):1268–71. PMID: 25932866. 10.1097/01.AOG.0000465192.34779.dc 25932866
59 Sockol LE, Epperson CN, Barber JP. Preventing postpartum depression: a meta-analytic review. Clin Psychol Rev. 2013;33(8):1205–17. PMID: 24211712. 10.1016/j.cpr.2013.10.004 24211712
60 Dennis CL, Dowswell T. Psychosocial and psychological interventions for preventing postpartum depression. Cochrane Database Syst Rev. 2013;2:CD001134. PMID: 23450532. 10.1002/14651858.CD001134.pub3 23450532
61 Kessler RC, Ustun TB. The World Mental Health (WMH) Survey Initiative Version of the World Health Organization (WHO) Composite International Diagnostic Interview (CIDI). Int J Methods Psychiatr Res. 2004;13(2):93–121. PMID: 15297906.15297906
62 Radloff L. The CES-D Scale: A Self-Report Depression Scale for Research in the General Population. Applied Psychological Measures. 1977;1:385.
63 Cox JL. Postnatal Depression: a Guide for Health Professionals. Edinburgh: Churchill Livingstone; 1986.
64 Programme UND. Human Development Report. New York, NY: United Nations; 2016. Available from: http://hdr.undp.org/sites/default/files/2016_human_development_report.pdf.
65 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
66 Brugha TS, Morrell CJ, Slade P, . Universal prevention of depression in women postnatally: cluster randomized trial evidence in primary care. Psychol Med. 2011;41(4):739–48. PMID: 20716383. 10.1017/S0033291710001467 20716383
67 Wiggins M, Oakley A, Roberts I, . The Social Support and Family Health Study: a randomised controlled trial and economic evaluation of two alternative forms of postnatal support for mothers living in disadvantaged inner-city areas. Health Technol Assess. 2004;8(32):iii, ix–x, 1–120. PMID: 15298823.15298823
68 Kenyon S, Jolly K, Hemming K, . Lay support for pregnant women with social risk: a randomised controlled trial. BMJ Open. 2016;6(3):e009203. PMID: 26936901. 10.1136/bmjopen-2015-009203 26936901
69 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629–34. PMID: 9310563.9310563
70 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49.
71 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
72 Dugravier R, Tubach F, Saias T, . Impact of a manualized multifocal perinatal home-visiting program using psychologists on postnatal depression: the CAPEDP randomized controlled trial. PLoS One. 2013;8(8):e72216. PMID: 23977257. 10.1371/journal.pone.0072216 23977257
73 MacArthur C, Winter HR, Bick DE, . Effects of redesigned community postnatal care on womens’ health 4 months after birth: a cluster randomised controlled trial. Lancet. 2002;359(9304):378–85. PMID: 11844507.11844507
74 Fontein-Kuipers YJ, Ausems M, de Vries R, . The effect of Wazzup Mama?! An antenatal intervention to prevent or reduce maternal distress in pregnancy. Archives of Women’s Mental Health. 2016;19(5):779–88. PMID: 26965708. 10.1007/s00737-016-0614-8 26965708
75 Howell E, Balbierz A, Wang J, . Reducing postpartum depressive symptoms among black and latina mothers: a randomized controlled trial. Obstet Gynecol. 2012;119(5):942–9. PMID: 22488220. 10.1097/AOG.0b013e318250ba48 22488220
76 Howell EA, Bodnar-Deren S, Balbierz A, . An intervention to reduce postpartum depressive symptoms: a randomized controlled trial. Arch Womens Ment Health. 2014;17(1):57–63. PMID: 24019052. 10.1007/s00737-013-0381-8 24019052
77 Dennis C, Hodnett E, Kenton L, . Effect of peer support on prevention of postnatal depression among high risk women: multisite randomised controlled trial. BMJ. 2009;338:a3064. PMID: 19147637.19147637
78 Hiscock H, Cook F, Bayer J, . Preventing early infant sleep and crying problems and postnatal depression: a randomized trial. Pediatrics. 2014;133(2):e346–54. PMID: 24394682. 10.1542/peds.2013-1886 24394682
79 Tandon SD, Perry DF, Mendelson T, . Preventing perinatal depression in low-income home visiting clients: a randomized controlled trial. J Consult Clin Psychol. 2011;79(5):707–12. PMID: 21806298. 10.1037/a0024895 21806298
80 Fisher J, Rowe H, Wynter K, . Gender-informed, psychoeducational programme for couples to prevent postnatal common mental disorders among primiparous women: cluster randomised controlled trial. BMJ Open. 2016;6(3):e009396. PMID: 26951210. 10.1136/bmjopen-2015-009396 26951210
81 Gorman L. Prevention of postpartum difficulties in a high risk sample [dissertation]: University of Iowa; 1997.
82 Morrell CJ, Spiby H, Stewart P, . Costs and effectiveness of community postnatal support workers: randomised controlled trial. BMJ. 2000;321(7261):593–8. PMID: 10977833.10977833
83 Munoz R, Le H, Ippen C, . Prevention of Postpartum Depression in Low-Income Women: Development of the Mamás y Bebés/Mothers and Babies Course. Cognitive and Behavioral Practice. 2007;14:70–83.
84 Le HN, Perry DF, Stuart EA. Randomized controlled trial of a preventive intervention for perinatal depression in high-risk Latinas. J Consult Clin Psychol. 2011;79(2):135–41. PMID: 21319897. 10.1037/a0022492 21319897
85 Werner EA, Gustafsson HC, Lee S, . PREPP: postpartum depression prevention through the mother-infant dyad. Archives of Women’s Mental Health. 2016;19(2):229–42. PMID: 26231973. 10.1007/s00737-015-0549-5 26231973
86 Zlotnick C, Johnson SL, Miller IW, . Postpartum depression in women receiving public assistance: pilot study of an interpersonal-therapy-oriented group intervention. Am J Psychiatry. 2001;158(4):638–40. PMID: 11282702. 10.1176/appi.ajp.158.4.638 11282702
87 Zlotnick C, Miller I, Pearlstein T, . A preventive intervention for pregnant women on public assistance at risk for postpartum depression. Am J Psychiatry. 2006;163(8):1443–5. PMID: 16877662.16877662
88 Zlotnick C, Capezza NM, Parker D. An interpersonally based intervention for low-income pregnant women with intimate partner violence: a pilot study. Arch Womens Ment Health. 2011;14(1):55–65. PMID: 21153559. 10.1007/s00737-010-0195-x 21153559
89 Ortiz Collado MA, Saez M, Favrod J, . Antenatal psychosomatic programming to reduce postpartum depression risk and improve childbirth outcomes: a randomized controlled trial in Spain and France. BMC Pregnancy Childbirth. 2014;14:22. PMID: 24422605. 10.1186/1471-2393-14-22 24422605
90 Dimidjian S, Goodman SH, Felder JN, . Staying well during pregnancy and the postpartum: A pilot randomized trial of mindfulness-based cognitive therapy for the prevention of depressive relapse/recurrence. J Consult Clin Psychol. 2016;84(2):134–45. PMID: 26654212. 10.1037/ccp0000068 26654212
91 Feinberg M, Kan M. Establishing family foundations: intervention effects on coparenting, parent/infant well-being, and parent-child relations. J Fam Psychol. 2008;22(2):253–63. PMID: 18410212. 10.1037/0893-3200.22.2.253 18410212
92 Woolhouse H, Mercuri K, Judd F, . Antenatal mindfulness intervention to reduce depression, anxiety and stress: a pilot randomised controlled trial of the MindBabyBody program in an Australian tertiary maternity hospital. BMC Pregnancy & Childbirth. 2014;14:369. PMID: 25343848. 10.1186/s12884-014-0369-z 25343848
93 Kozinszky Z, Dudas R, Devosa I, . Can a brief antepartum preventive group intervention help reduce postpartum depressive symptomatology? Psychother Psychosom. 2012;81(2):98–107. PMID: 22261988. 10.1159/000330035 22261988
94 Leung SS, Lam TH. Group antenatal intervention to reduce perinatal stress and depressive symptoms related to intergenerational conflicts: a randomized controlled trial. International Journal of Nursing Studies. 2012;49(11):1391–402. PMID: 22818396. 10.1016/j.ijnurstu.2012.06.014 22818396
95 Cooper PJ, De Pascalis L, Woolgar M, . Attempting to prevent postnatal depression by targeting the mother-infant relationship: a randomised controlled trial. Prim Health Care Res Dev. 2015;16(4):383–97. PMID: 25381790. 10.1017/S1463423614000401 25381790
96 Cohen J. A power primer. Psychol Bull. 1992;112(1):155–9. PMID: 19565683.19565683
97 Milgrom J, Schembri C, Ericksen J, . Towards parenthood: an antenatal intervention to reduce depression, anxiety and parenting difficulties. J Affect Disord. 2011;130(3):385–94. PMID: 21112641. 10.1016/j.jad.2010.10.045 21112641
98 Leung SS, Lee AM, Wong DF, . A brief group intervention using a cognitive-behavioural approach to reduce postnatal depressive symptoms: a randomised controlled trial. Hong Kong Medical Journal. 2016;22: Suppl 2:S4–8. PMID: 26908335.26908335
99 Songoygard K, Stafne S, Evensen K, . Does exercise during pregnancy prevent postnatal depression? A randomized controlled trial. Acta Obstet Gynecol Scand. 2012;91(1):62–7. PMID: 21880023. 10.1111/j.1600-0412.2011.01262.x 21880023
100 Perales M, Refoyo I, Coteron J, . Exercise during pregnancy attenuates prenatal depression: a randomized controlled trial. Evaluation & the Health Professions. 2015;38(1):59–72. PMID: 24872442. 10.1177/0163278714533566 24872442
101 Norman E, Sherburn M, Osborne RH, . An exercise and education program improves well-being of new mothers: a randomized controlled trial. Phys Ther. 2010;90(3):348–55. PMID: 20056720. 10.2522/ptj.20090139 20056720
102 Heh SS, Fu YY. Effectiveness of informational support in reducing the severity of postnatal depression in Taiwan. J Adv Nurs. 2003;42(1):30–6. PMID: 12641809.12641809
103 Hayes B, Muller R, Bradley B. Perinatal depression: a randomized controlled trial of an antenatal education intervention for primiparas. Birth. 2001;28(1):28–35. PMID: 11264626.11264626
104 Maimburg RD, Vaeth M. Postpartum depression among first-time mothers - results from a parallel randomised trial. Sexual & reproductive healthcare: official journal of the Swedish Association of Midwives. 2015;6(2):95–100. PMID: 25998877. 10.1016/j.srhc.2015.01.003 25998877
105 Dennis CL. The effect of peer support on postpartum depression: a pilot randomized controlled trial. Can J Psychiatry. 2003;48(2):115–24. PMID: 12655910. 10.1177/070674370304800209 12655910
106 Reid M, Glazener C, Murray G, . A two-centred pragmatic randomised controlled trial of two interventions of postnatal support. BJOG. 2002;109(10):1164–70. PMID: 12387471.12387471
107 Stamp GE, Williams AS, Crowther CA. Evaluation of antenatal and postnatal support to overcome postnatal depression: a randomized, controlled trial. Birth. 1995;22(3):138–43. PMID: 7575861.7575861
108 Morrell CJ, Spiby H, Stewart P, . Costs and benefits of community postnatal support workers: a randomised controlled trial. Health Technol Assess. 2000;4(6):1–100. PMID: 10858637.10858637
109 Hiscock H, Wake M. Randomised controlled trial of behavioural infant sleep intervention to improve infant sleep and maternal mood. BMJ. 2002;324(7345):1062–5. PMID: 11991909.11991909
110 Davis K, Goodman SH, Leiferman J, . A randomized controlled trial of yoga for pregnant women with symptoms of depression and anxiety. Complement Ther Clin Pract. 2015;21(3):166–72. PMID: 26256135. 10.1016/j.ctcp.2015.06.005 26256135
111 Priest S, Henderson J, Evans S, . Stress debriefing after childbirth: a randomised controlled trial. Med J Aust. 2003;178(11):542–5. PMID: 12765500.12765500
112 Di Blasio P, Camisasca E, Caravita SC, . The Effects of Expressive Writing on Postpartum Depression and Posttraumatic Stress Symptoms. Psychological Reports. 2015;117(3):856–82. PMID: 26595300. 10.2466/02.13.PR0.117c29z3 26595300
113 Excellence NIfHaC. Postnatal Care Up to 8 Weeks After Birth. https://www.nice.org.uk/guidance/cg37/chapter/1-Recommendations. Accessed: January 17, 2018.
114 Gartlehner G, Hansen RA, Reichenpfader U, . Drug Class Review: Second-Generation Antidepressants: Final Update 5 Report. Drug Class Review: Second-Generation Antidepressants: Final Update 5 Report. Portland (OR): Oregon Health & Science University; 2011.
115 O’Connor EA, Whitlock EP, Beil TL, . Screening for depression in adult patients in primary care settings: a systematic evidence review. Ann Intern Med. 2009;151(11):793–803. PMID: 19949145. 10.7326/0003-4819-151-11-200912010-00007 19949145
116 Weissman AM, Levy BT, Hartz AJ, . Pooled analysis of antidepressant levels in lactating mothers, breast milk, and nursing infants. Am J Psychiatry. 2004;161(6):1066–78. PMID: 15169695. 10.1176/appi.ajp.161.6.1066 15169695
117 Haga SM, Drozd F, Brendryen H, . Mamma mia: a feasibility study of a web-based intervention to reduce the risk of postpartum depression and enhance subjective well-being. JMIR Research Protocols. 2013;2(2):e29. PMID: 23939459. 10.2196/resprot.2659 23939459
118 Le HN, Perry DF, Genovez M, . In their own voices: Latinas’ experiences with a randomized controlled trial. Qualitative Health Research. 2013;23(6):834–46. PMID: 23539092. 10.1177/1049732313482591 23539092
119 Jardri R, Pelta J, Maron M, . Predictive validation study of the Edinburgh Postnatal Depression Scale in the first week after delivery and risk analysis for postnatal depression. J Affect Disord. 2006;93(1–3):169–76. PMID: 16644021. 10.1016/j.jad.2006.03.009 16644021
120 Hofmann SG, Asnaani A, Vonk IJ, . The Efficacy of Cognitive Behavioral Therapy: A Review of Meta-analyses. Cognit Ther Res. 2012;36(5):427–40. PMID: 23459093. 10.1007/s10608-012-9476-1 23459093
121 Sudak DM. Cognitive behavioral therapy for depression. Psychiatr Clin North Am. 2012;35(1):99–110. PMID: 22370493. 10.1016/j.psc.2011.10.001 22370493
122 Gartlehner G, Gaynes BN, Amick HR, . Comparative Benefits and Harms of Antidepressant, Psychological, Complementary, and Exercise Treatments for Major Depression: An Evidence Report for a Clinical Practice Guideline From the American College of Physicians. Ann Intern Med. 2016;164(5):331–41. PMID: 26857743. 10.7326/M15-1813 26857743
123 Mothers and Babies Course. https://nrepp.samhsa.gov/ProgramProfile.aspx?id=32#hide4. Accessed: May 1, 2018.
124 Institute IP. About IPT. https://iptinstitute.com/about-ipt/. Accessed: January 9, 2018.
125 Cuijpers P, Geraedts AS, van Oppen P, . Interpersonal psychotherapy for depression: a meta-analysis. Am J Psychiatry. 2011;168(6):581–92. PMID: 21362740. 10.1176/appi.ajp.2010.10101411 21362740
126 Mokhber N, Namjoo M, Tara F, . Effect of supplementation with selenium on postpartum depression: a randomized double-blind placebo-controlled trial. J Matern Fetal Neonatal Med. 2011;24(1):104–8. PMID: 20528216. 10.3109/14767058.2010.482598 20528216
127 Gur EB, Gokduman A, Turan GA, . Mid-pregnancy vitamin D levels and postpartum depression. Eur J Obstet Gynecol Reprod Biol. 2014;179:110–6. PMID: 24965990. 10.1016/j.ejogrb.2014.05.017 24965990
128 Miyake Y, Tanaka K, Okubo H, . Dietary vitamin D intake and prevalence of depressive symptoms during pregnancy in Japan. Nutrition. 2015;31(1):160–5. PMID: 25466661. 10.1016/j.nut.2014.06.013 25466661
129 Austin MP, Lumley J. Antenatal screening for postnatal depression: a systematic review. Acta Psychiatr Scand. 2003;107(1):10–7. PMID: 12558536.12558536
130 Dennis CL. Can we identify mothers at risk for postpartum depression in the immediate postpartum period using the Edinburgh Postnatal Depression Scale? J Affect Disord. 2004;78(2):163–9. PMID: 14706728.14706728
131 Edwards B, Galletly C, Semmler-Booth T, . Does antenatal screening for psychosocial risk factors predict postnatal depression? A follow-up study of 154 women in Adelaide, South Australia. Aust N Z J Psychiatry. 2008;42(1):51–5. PMID: 18058444. 10.1080/00048670701739629 18058444
132 Ingram J, Taylor J. Predictors of postnatal depression: using an antenatal needs assessment discussion tool. J Reprod Infant Psychol. 2007;25(3):210–22.
133 Teissedre F, Chabrol H. Detecting women at risk for postnatal depression using the Edinburgh Postnatal Depression Scale at 2 to 3 days postpartum. Can J Psychiatry. 2004;49(1):51–4. PMID: 14763678. 10.1177/070674370404900108 14763678
134 Austin MP, Colton J, Priest S, . The antenatal risk questionnaire (ANRQ): acceptability and use for psychosocial risk assessment in the maternity setting. Women Birth. 2013;26(1):17–25. PMID: 21764399. 10.1016/j.wombi.2011.06.002 21764399
135 Davis S, Cross J, Lind BK. Exploring the Postpartum Adjustment Questionnaire as a predictor of postpartum depression. J Obstet Gynecol Neonatal Nurs. 2008;37(6):622–30. PMID: 19012712. 10.1111/j.1552-6909.2008.00286.x 19012712
136 Beck CT, Records K, Rice M. Further development of the Postpartum Depression Predictors Inventory-Revised. J Obstet Gynecol Neonatal Nurs. 2006;35(6):735–45. PMID: 17105638. 10.1111/j.1552-6909.2006.00094.x 17105638
137 Honey K, Bennet P, Morgan M. Predicting postnatal depression. J Affect Disord. 2003;76:201–10. 12943950
138 Austin MP, Hadzi-Pavlovic D, Saint K, . Antenatal screening for the prediction of postnatal depression: validation of a psychosocial Pregnancy Risk Questionnaire. Acta Psychiatr Scand. 2005;112(4):310–7. PMID: 16156839. 10.1111/j.1600-0447.2005.00594.x 16156839
139 Iliadis SI, Koulouris P, Gingnell M, . Personality and risk for postpartum depressive symptoms. Arch Womens Ment Health. 2015;18(3):539–46. PMID: 25369905. 10.1007/s00737-014-0478-8 25369905
140 Webster J, Pritchard MA, Creedy D, . A simplified predictive index for the detection of women at risk for postnatal depression. Birth. 2003;30(2):101–8. PMID: 12752167.12752167
141 Webster J, Hall L, Somville T, . Prospective testing of the Brisbane Postnatal Depression Index. Birth. 2006;33(1):56–63. PMID: 16499532. 10.1111/j.0730-7659.2006.00074.x 16499532
142 Sutter-Dallay AL, Giaconne-Marcesche V, Glatigny-Dallay E, . Women with anxiety disorders during pregnancy are at increased risk of intense postnatal depressive symptoms: a prospective survey of the MATQUID cohort. Eur Psychiatry. 2004;19(8):459–63. PMID: 15589703. 10.1016/j.eurpsy.2004.09.025 15589703