# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Elisabeth Kato, MD, and Justin Mills, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Drs. Sherryl Goodman, Michael O’Hara, Barbara Yawn, and Susan Kornstein for their content expertise and review of the draft report; Brittany U. Carter, DSc, MPH, for her assistance with scoping; and Smyth Lai, MLS, and Katherine Essick, BS, at the Kaiser Permanente Center for Health Research for technical and editorial assistance.