# Chapter 4 Discussion

## Summary of Evidence

Counseling interventions had the strongest evidence base, particularly depression-focused CBT and IPT interventions among women at increased risk of PND, with an estimated 39 percent reduction in the risk of PND at up to 6 months postpartum (pooled RR=0.61 [95% CI, 0.47 to 0.78], k=17, n=3094, I^2^=39%). We judged these results to be reasonably consistent and reasonably precise, and applicable to women with symptoms or a history of depression in the United States, particularly among racial/ethnic minority women and those who are socioeconomically disadvantaged (Table 5). This corresponds to a NNT of 13.5 (95% CI, 9.9 to 23.9), assuming a 19 percent baseline risk of developing PND (Table 6).

Table 5 Strength of Evidence Among 50 Included Trials (n=22,385), by Intervention Type

Key question | No. of Studies, (No. of Observations) | Summary of findings | Consistency/precision | Reporting bias | Overall study quality | Body of evidence limitations | EPC assessment of overall strength of evidence | Applicability
KQ1 . Counseling | 20 (4107) | Counseling interventions reduced the risk of perinatal depression, primarily using cognitive behavioral therapy and interpersonal therapy. In pooled analyses, the likelihood of perinatal depression was 39% lower in intervention participants than controls (pooled RR=0.61 [95% CI, 0.47 to 0.78], 17 trials, n=3094, I^2^=39%, ARD range +1.3% to −31.8%). Depression symptom severity was reduced by 1.5 points more in intervention than control participants (WMD= −1.51 [95% CI −2.84 to −0.18], 13 trials, n=1367, I^2^=61%) | Reasonably consistent, reasonably precise | Suspected | Good: 2 Fair: 18 | Small studies effect suggests possible overestimate of effect size, many small n trials, relatively few good-quality trials. Dichotomous depression outcomes are a mix of incidence, prevalence, and being above a severity cutoff. | Moderate | 60% conducted in the US, most targeting women at increased risk of PND, most initiating the intervention during pregnancy. Interventions are not widely available and require specialized training.
Health System | 3 (5321) | All three health system interventions reduced the risk of perinatal depression by 29% to 69%, although the pooled effect was not statically significant (REML RR=0.58 [95% CI, 0.22 to 1.53], k=3, n=4738, I^2^=66%, ARD range −3.1% to −13.1%). One trial each reported improvements in anxiety and SF-36 mental health component scores, but the third found no difference in SF-36 scores. | Reasonably consistent, Imprecise | None detected | Good: 0 Fair: 3 | One trial reported results only for the subset of women who had not developed elevated symptoms by 6 weeks postpartum. One trial was a non-randomized clinical trial | Low | Problematic. All conducted outside the US in health care systems that are very different from the US (e.g., postpartum home visitors are part of usual care)
Physical Activity | 3 (1200) | One of the physical activity trials demonstrated a statistical significant reduction in the risk of perinatal depression, with 12.2% of intervention participants exceeding an EPDS threshold vs 24.7% of control participants. Absolute risk differences were smaller and not statistically significant in the other trials (range −1.3% to −5.0%). | Reasonably consistent, Imprecise | None detected | Good: 1 Fair: 2 | Small body of evidence, only one study showed statistically significant between-group differences | Insufficient | None conducted in the US, only included unselected populations, however studies covered both pregnant and postpartum women
Education | 6 (2949) | Most trials did not find a benefit, however one of the two US-based trials found a promising short-term benefit of a brief PND education session in the hospital after delivery with one brief followup phone call (6.3% of IG women EPDS≥10, vs. 11.4% in CG, aOR=0.45 [95% CI 0.21 to 0.92]). Effect size was smaller and not statistically significant upon replication. | Inconsistent, Imprecise | None detected | Good: 2 Fair: 4 | Wide variety of approaches, minimal replication or similar interventions; the one replicated intervention had mixed findings | Insufficient | Only 2 trials of the same intervention conducted in the US
Supportive Interventions | 7 (4569) | Three of the trials showed benefits of treatment, although effects were either not large, of marginal statistical significance, or based on a very small sample. Phone-based support by trained peers with history of PND showed most promise. | Inconsistent, Imprecise | None detected | Good: 2 Fair: 5 | Wide variety of approaches with minimal replication, adherence was very low in one of two non-directive support group interventions | Insufficient | None conducted in the US, some embedded in health care systems with very low applicability to the US.
Sleep | 3 (980) | Mixed results, but some promising findings, including a 43% reduction in the odds of PND in one study (aOR=0.57 [95% CI 0.34 to 0.94]) | Inconsistent, Imprecise | None detected | Good: 0 Fair: 3 | Low | Insufficient | Only one small trial conducted in the US (n=54); targeted both early and later postpartum phases.
Yoga | 1 (46) | No statistically significant or potentially clinically important differences between group in depression severity (MD in change in depression symptoms at post-test: 0.1 [95% CI −.3.2 to 3.5]) or anxiety. | Consistency NA, Imprecise | None detected | Good: 0 Fair: 1 | Single small study | Insufficient | Conducted in the US, among women with elevated anxiety and depressive symptoms
Debriefing | 2 (2786) | No benefit of debriefing the birth experience (pooled RR=1.04 [95% CI, 0.88 to 1.22], k=2, n=2662 I^2^=27%) | Reasonably consistent, reasonably precise | None detected | Good: 0 Fair: 2 | Only 2 trials | Low | Neither conducted in the US
Expressive Writing | 1 (120) | Expressive writing not clearly associated with PND risk in single relatively small study (RR=0.55 [95% CI 0.20 to 1.53]). | Consistency NA, Imprecise | None detected | Good: 0 Fair: 1 | Single small study | Insufficient | Not conducted in the US
Anti-depressants | Sertraline: 1 (22) Nortriptyline: 1 (58) | Sertraline may reduce the risk of PND, but nortriptyline is unlikely to reduce the risk of PND | Consistency NA, Imprecise | None detected | Good: 0 Fair: 2 | Single very small study for each agent | Insufficient | Conducted in the US, recruitment through healthcare setting, both in women with a history of PND
Omega-3 fatty acids | 2 (227) | Supplementation with omega3 fatty acids (DHA, EPA) is not associated with a reduced likelihood of PND (pooled RR=1.71 [95% CI 0.70 to 4.17], k=2, n=204, I^2^=0) | Reasonably consistent, reasonably precise | None suspected | Good: 1 Fair: 1 | Very small body of evidence | Low | Both US-based, unselected and atrisk populations, including pregnant and post-partum women
KQ2 . Harms of interventions | Behavior-based: 0 (0) Omega-3 fatty acids: 1, (126) Nortriptyline: 1 (58) Sertraline: 1 (22) | Adverse events were not reported in behavior-based trials, but other outcomes consistently trended in direction of benefit or no effect. No adverse events were reported in either treatment group in one trial of omega-3 fatty acids. Nortriptyline was associated with constipation (78% vs. 22%), but there were no differences in withdrawal due to adverse effects. One patient taking nortriptyline converted to mania (vs. none taking placebo). Sertraline with associated with an increased risk of dizziness (57% vs. 13%) and drowsiness (100% vs 50%). Three patients taking sertraline withdrew due to adverse effect (vs. none taking placebo). One patient taking sertraline converted to mania (vs. none taking placebo). | Consistency NA, Imprecise | None suspected | Good: 1 Fair: 2 | For the antidepressants, underpowered to detect serious adverse events such as conversion to mania | Behavior-based, DHA: Low Others: Insufficient | Antidepressant trials conducted in the US.

Abbreviations: AD = Antidepressants; aOR = Adjusted Odds Ratio; CG = Control group; CI = Confidence interval; DHA = Docosahexaenoic Acid; EPA = Eicosapentaenoic acid; EPDS = Edinburgh Postnatal Depression Scale; IG = Intervention group; K = number of studies; KQ = Key question; MD = Mean difference; NA = Not applicable; PA = Physical activity; PND = Postnatal depression; DEP = Depression; REML = Restricted maximum likelihood model; RR = Risk Ratio; SES = Socioeconomic status; SF-36 = Short form-36; US = United States; Vs = Versus

Table 6 Number Needed to Treat to Avoid One Case of Perinatal Depression for Counseling Interventions, Across Three Levels of Risk

Percent expected to develop PND in usual care | Number needed to Treat | 95% Confidence interval
10% | 25.6 | (18.9 to 45.5)
19% | 13.5 | (9.9 to 23.9)
31% | 8.3 | (6.1 to 14.7)

Abbreviations: CI = Confidence interval; PND = Postnatal depression

Three different health system-level interventions were also effective in health care settings outside the United States, suggesting that similar interventions developed in U.S.-based health care systems may have the potential to be effective. Findings were consistent across the three intervention approaches; however, their applicability to the United States was limited and the pooled estimate was imprecise and not statistically significant. In all three cases, usual care included home visitation, which may be a valuable intervention itself. This makes it difficult to generalize the effects to the United States but suggests the potential for even greater benefit, compared with usual care in the United States.

Several other approaches also showed promise in general perinatal populations but need more research due to the small number of women studied. These include physical activity, infant sleep advice, and a brief in-hospital educational session with 2-week followup. In addition, case management with home-based support by lay pregnancy outreach workers was effective for women with social risk factors (in the United Kingdom),^68^ and peer counseling^77,^ ^105^ by women with a history of PND showed promise for ameliorating the risk of PND in women experiencing depressive symptoms in the early postpartum period, but based on only one to two trials each. The two studies of nondirective support groups were hampered by low uptake and did not reduce the risk of depression.^106,^ ^107^ One small study (n=22) suggested that prophylactic initiation of sertraline immediately after birth may reduce the risk of PND, but may also increase the risk of dizziness and drowsiness, and a possibility of increased risk of conversion to mania could not be ruled out.^45^ There was evidence to suggest that omega-3 fatty acids^50,^ ^51^ and birth-experience debriefing^44,^ ^111^ were not effective in reducing the risk of PND. The latter finding is consistent with the United Kingdom National Health Service recommendation against routine use of debriefing interventions after delivery.^113^ In addition, one small (n=58) trial of nortriptyline administered immediately postpartum showed no reduction in the risk of depression, but did report an increased risk of constipation; a possibility of increased risk of conversion to hypomania could not be ruled out.^46^

Broadly, antidepressants can be an important tool for treatment of depression, but have been associated with a number of serious or potentially serious adverse events, including suicidality (in young adults), hyponatremia, seizures, gastrointestinal bleeding, and serotonin syndrome.^114,^ ^115^ In addition, use of second generation antidepressants during pregnancy has been associated with an increased risk of a number of serious pregnancy and neonatal outcomes, and the use of sertraline specifically has been associated with increased risk of miscarriage and vaginal bleeding, and thus are likely best reserved for those with a treatment need (not prevention), after careful weighing of risks and benefit.^37^ While antidepressants are secreted in breast milk, sertraline tends to be undetectable in infant blood serum, making it a relatively better choice for use while breastfeeding.^116^

## Comparison With Other Reviews

Our findings were very similar to those reported in a 2013 Cochrane review on psychosocial and psychological interventions to prevent PND.^60^ This review had a similar scope, although it searched only through December 2012. It found that women who received a psychosocial or psychological intervention were 22 percent less likely to develop PND, compared with usual care (pooled RR=0.78 [95% CI, 0.66 to 0.93, k=20, n=14,727)]. They listed the following as promising approaches: intensive, individualized home-visiting approaches, peer-based telephone support, and interpersonal therapy. Similarly, another review of randomized and quasi-randomized controlled trials of interventions designed to prevent PND found a 33 percent reduction in the odds of depressive episodes by 6 months postpartum, after excluding outliers (pooled OR=0.67 [95% CI, 0.52 to 0.85], k=26, I^2^=46%), again searching through December 2012.^59^ They found no study or intervention characteristics that showed a statistically significant association with effect size, including intervention type, control group type, intervention timing (pregnancy vs. postpartum), type of prevention (indicated, selected, universal), outcome measurement instrument, whether women with current major depressive episode (MDE) were excluded, psychotherapy approach (CBT vs. IPT), and whether the intervention was administered in group or individual sessions.

## Harms and Acceptability of Behavior-Based Interventions

None of the behavior-based interventions reported on the potential or actual harms of their interventions; however, across a large number of reported outcomes, no pattern emerged suggesting these interventions were likely to be harmful. Acceptability of the intervention was reported by several studies and was overall positive. Six studies of counseling-focused interventions reported acceptability measures from participants, and all indicated that participants felt that the interventions were beneficial and enjoyable.^53,^ ^83,^ ^90,^ ^92,^ ^95,^ ^117^ One study found that most women (>90%) reported that they planned on using the techniques discussed in their everyday lives,^83^ while another study of counseling and education by home visitors found that the intervention group felt better supported than the control group, both emotionally and practically (p<0.004).^95^ Two U.S.-based trials of CBT that specifically targeted low-income Latina women—who are at particularly high risk of PND—had relatively low adherence. However, one had high acceptability ratings^83^ and the other reported many positive comments from in-depth qualitative interviews with a representative subset of participants (including those who attended more than half of the sessions, fewer than half the sessions, and women in the usual care group).^84^ Through these interviews, they determined that women in the CBT group felt supported and actively used many of the cognitive and behavioral techniques covered by the course. In addition, they found that the frequent contact with the research team became a source of valuable support for both intervention and usual care participants. They hypothesized that the usual care group’s participation in the study assessments and other contact with study staff may have acted as an active intervention and lead to the low rates of depression in the control group.^118^ For example, one woman in the usual care group said, about the research staff person she worked with, “I would talk to her and would tell her all my personal matters. The Mothers and Babies [project] was helpful: being able to talk to someone and listen to the advice they always give me. This is an unfamiliar country for us.”

Only one of the trials examining a health system-focused intervention reported measures of satisfaction and found that overall satisfaction with care was not different between the intervention and usual care groups.^73^ Women in the intervention group, however, were more likely than those in the usual care group to rate their care as better than expected (p=0.009). The intervention in this trial involved training midwives in specially developed guidelines for postpartum care. Two studies with education-focused interventions^80,^ ^102^ reported that participants indicated that the content presented was relevant, useful, and comprehensible, however, some complained about the length of the one-time 6-hour session.^80^ All but two^68,^ ^107^ support-focused studies evaluated participant acceptability, with generally positive results. Five studies reported that the majority of participants (70% to 88%) indicated that they were satisfied with their experience.^67,^ ^77,^ ^82,^ ^105,^ ^106^ However, in one study arm consisting of an enhanced referral process to community support groups only 45 percent rated their support contacts as helpful.^67^ Two of three sleep-focused interventions evaluated participant satisfaction, finding that the mothers in the intervention groups were more satisfied with the sleep patterns of their infants than women in the control groups and that the majority (95%) of women would recommend the program to their friends.^78,^ ^109^ Similarly, both the yoga-based intervention^110^ and the two debriefing studies^44,^ ^111^ reported that the majority of participants found the interventions helpful and had high levels of satisfaction, although neither of these approaches reduced depressive symptoms over usual care.

## Effect of Intervention Timing

The included evidence suggested that interventions can be effective when delivered during pregnancy, the postpartum period, or both. The counseling interventions almost all began during the second trimester of pregnancy, and quite a few included postpartum sessions as well as prenatal sessions, particularly the IPT interventions. Two of the CBT-based “Mothers and Babies” trials recruited both pregnant and postpartum women, but they did not report on whether the intervention was more or less effective at either stage. Subgroup meta-analyses indicated very similar effects for trials that were limited to the prenatal stage and to the postpartum stage, and that spanned both stages (Figure 2, under “Intervention Timing”), and meta-regressions did not find statistically significant associations between intervention timing and effect size, after controlling for whether the population was selected based on depression-related factors. However, this analysis had limited utility because there was little opportunity to explore the effects of intervention timing among similar interventions.

## Identification of Persons at Increased Risk of Perinatal Depression

Different interventions may be appropriate for individuals with different risk profiles, and we could not provide clear guidance on the ideal method for determining who needs what intervention based on the included literature. Among counseling interventions, increased depressive symptoms and a previous history of depression were the most common inclusion criteria, but many of the trials with these selection criteria were limited to women with low socioeconomic status, among trials conducted in the United States, and some had other risk criteria that could additionally qualify participants.

Overall, 26 of the trials selected women at increased risk for PND, according to a very wide range of definitions that included having a personal or family history of depression or PND, elevated depressive symptoms, socioeconomic risk factors (e.g., low income, single/without partner, adolescent, recent intimate partner violence) or mental health-related factors (e.g., elevated anxiety symptoms, history or significant negative life events). Twelve trials selected women solely on the basis of depression symptoms or history.^38,^ ^45,^ ^46,^ ^50,^ ^77,^ ^79,^ ^83,^ ^84,^ ^90,^ ^102,^ ^105,^ ^110^ Four of these included women solely because they had an elevated score on the EPDS,^77,^ ^102,^ ^105,^ ^110^ and three included women only if they had a previous episode of major depressive disorder^90^ and postpartum-onset major depressive disorder (ignoring current symptoms).^45,^ ^46^ The remaining five included women with either elevated symptoms or a history of depression. After the EPDS, the CES-D was the most commonly utilized tool for identifying women at risk for developing postpartum depression in the included trials; all four CBT-based “Mothers and Babies” trials included women with a CES-D score of 16 or higher or a history of depression.^38,^ ^79,^ ^83,^ ^84^ These trials also recruited women from low-socioeconomic status (SES) settings (women in a home-visiting program for low-income women,^38,^ ^79^ Latina women from community clinics^84^ and urban public hospitals),^83,^ ^84^ so most or all of the participants had additional SES-related risk factors.

One study of the accuracy of the EPDS to predict future PND found that a cutoff of 9 or higher at 3 to 5 days postpartum had 82 percent sensitivity, 95 percent specificity, and 43 percent positive predictive value (PPV) for a diagnosis of major or minor depression at 8 weeks postpartum.^119^ Of the trials included in our review that used EPDS to identify women at risk for depression, none reported a clinical diagnosis outcome, so we could not calculate any performance characteristics of the EPDS. We found no information in the literature on the accuracy of the CES-D to predict future PND. In the four “Mothers and Babies” CBT trials included in this review,^38,^ ^79,^ ^83,^ ^84^ which selected women who had either a CES-D score greater than or equal to 16 or a lifetime history of a major depressive episode, there was a wide range in the proportion of participants who developed a major depressive episode among control group participants (reflecting PPV), ranging from 0 (at 4 and 13 weeks postpartum)^83^ to 33.3 percent (at 32 weeks postpartum).^79^ The wide range of PPVs may be related to differences in usual care, study assessment methods, or differences in the populations. Beyond the CES-D and EPDS, the literature on predicting future PND includes a variety of patient- and clinician-administered tools, but results have been modest in many cases and would need to be replicated to support their use in routine clinical practice. More detail on what is known about the accuracy of screening instruments to predict PND is provided in Appendix H.

## Interventions for Perinatal Depression

CBT is one of the most commonly used psychological approaches for treatment of depression and was the foundation of several interventions included in this review. CBT describes a group of interventions based on the core premise that emotional distress and behavioral problems are caused by maladaptive or unhealthy thoughts and that therapeutic interventions to change negative cognitions or schemas can lead to positive changes in both mood and behavior.^120^ Common therapeutic techniques include patient education, goal-setting, interventions to identify and modify maladaptive thought patterns, and behavioral activation, usually with concrete “homework” assignments between sessions.^121^ A 2012 review of meta-analyses reported that CBT for depression was more effective than control conditions (e.g., waiting list or no treatment), but reported mixed findings from studies that compared the effectiveness of CBT with other active treatments (e.g., psychodynamic therapy, problem-solving therapy, interpersonal psychotherapy) or psychotropic medications.^120^ Overall, the review concluded that CBT was either equally effective to or more effective than other psychological approaches, and equally effective as psychopharmacological treatments for depression. Some studies have indicated that combination therapy with both CBT and psychopharmacology may be more effective than treatment with CBT alone.^122^

In the context of prevention, the Moms and Babies course used a more psychoeducational format, but covered the material commonly used for treatment of depression. For example, in one of the six-session versions that was implemented in the context of a home visiting program, the six sessions were divided into three two-session modules that mapped onto the core CBT concepts of pleasant activities, thoughts, and contact with others.^38^ Each session contained didactic instruction on core content, along with activities and group discussion. The activities and group discussion focused largely on introducing and practicing the use of core skills (e.g., strategies to reduce harmful thought patterns, ways to effectively ask for support). In keeping with the CBT orientation of the intervention, at the end of each session a personal project was assigned which asked participants to practice using one or more of the skills taught during the session. The course was designed to be provided by master’s level health professionals, paraprofessionals with mental health training and supervision, and home visitors. It can be delivered individually as well as in groups, course manuals and other dissemination materials have been developed and are freely available,^123^ and facilitator training courses are offered by the developers.

One of the other CBT interventions included elements of mindfulness therapy in addition to cognitive behavioral skills, and showed a large beneficial effect (64% reduction in the incidence of depression at 6 months postpartum).^90^ In addition to training and practice in mindfulness practices and meditation, CBT-related topics included: “opening to difficulty and uncertainty” (increasing awareness of thoughts, emotions, and sensations rather than engaging automatic patterns; increasing understanding of signs of depression and anxiety); “thoughts are not facts” (recognizing patterns of thoughts that tend to recur; shifting from being caught up in one’s thoughts to seeing thoughts as mental events that are not necessarily valid truths); “how can I best care for myself” (increasing self-care, focusing on the use of nonjudgmental attention during meditation; use of lovingkindness meditation; awareness of the influence of activities on mood; awareness of relapse signatures); “expanding circles of care” (interpersonal relationships, social support, beliefs that interfere with accessing social support, skill-building asking for help; important or reaching out to others to support wellness and prevent relapse); and “looking to the future” (consolidating relapse prevention plans, reinforce links between mindfulness practices and prevention of depression).

Another psychological approach that has been studied for preventing PND is IPT. IPT is a time-limited, structured, intervention approach that focuses on treating interpersonal issues that are thought to contribute to the development or maintenance of psychological disorders.^124^ Treatment is usually completed within 6 to 20 sessions. Commonly used therapeutic techniques include the use of exploratory questions (i.e., open-ended and clarifying questions), role-playing, decision analysis, and communication analysis. A 2011 meta-analysis of 38 studies assessing the effectiveness of IPT for the treatment of depression concluded that IPT was more effective than control conditions and equally effective as other psychological treatments, but less effective than psychopharmacological treatments.^125^ Combination therapy with IPT and pharmacological treatment was not more effective than IPT alone for the treatment of depression, but combination therapy was more effective than pharmacological treatment alone for the prevention of relapse. The IPT-based ROSE program for prevention of perinatal depression that was included in the current review, which resulted in a 49 percent reduction in the incidence of depression at 6 months postpartum, focused on managing role transitions in the transition to motherhood.^42^ Specific elements included developing a support system, developing effective communication skills to manage relationship conflicts before and after the birth of their baby, goal setting, and psychosocial resources for new mothers.

## Limitations of the Review

The included studies are subset of the larger body of evidence on interventions to promote maternal well-being during pregnancy and the first year postpartum. One of the challenges with this review was determining whether PND prevention was truly an a priori aim when the intervention did not explicitly target PND. For example, we excluded some studies with aims such as maternal well-being (defined broadly), infant attachment, and maternal responsiveness that reported depression-related outcomes but that did not appear to have depression as an a priori aim of the study. However, it is possible that we missed some studies that had depression as a specific aim (but did not describe it as such in the publication) and may have included some trials that added the depression prevention aim post hoc after determining that their intervention was effective in preventing depression. The concern with including any perinatal study reporting a maternal depression outcome (vs. attempting to limit studies based on their aims) is that studies with statistically significant findings might be more likely to report this as a secondary outcome than studies in which there were no between-group differences in depression, biasing the synthesized results in favor of preventive interventions.

We chose dichotomous depression status as our primary outcome, both because of its clinical utility and because it was the most commonly reported outcome in this body of evidence. For most analyses, we combined the outcome of exceeding a symptom score cutoff with incidence and prevalence of depressive disorders, although incidence and prevalence are cleaner outcomes and likely have the greatest clinical meaning. Our sensitivity analyses suggested that results were not being overstated by including the outcomes of exceeding cutoffs. This approach had the effect of making absolute rates highly variable, although analyses suggested that the relative effects were likely similar across outcome types. We also believe exceeding symptom cutoffs are clinically important outcomes. Persons with high levels of depressive symptoms could likely benefit from some type of support or counseling even if they do not meet criteria for major depressive disorder (MDD)—these individuals are still experiencing high levels of distress and some may meet criteria for other disorders, such as anxiety-related disorders. Thus, we believe it is reasonable to combine the outcome of exceeding symptom cutoff scores with incidence and prevalence.

Finally, both the overall body of evidence and counseling intervention trials had statistically significant small studies effects. Smaller trials also tended to use interventions that more directly targeted depression and that offered more intensive interventions, so this effect may be in part due to these and other study characteristics. However, we could not determine to what extent the effect might be biasing results and overestimating the effect size.

## Limitations of the Evidence and Future Research Needs

Across the body of literature, there were relatively few good-quality trials, and we excluded approximately one-third of the trials within the scope of this review due to their poor quality. Likely many of these were pilot studies that were not designed to provide data on effectiveness of the intervention or that used intervention approaches that proved infeasible and so were abandoned in the form that was studied. However, some of these studies may have provided useful information had they been conducted and reported in such a way that they met USPSTF quality standards. This field would benefit from more consistent reporting of randomization procedures and allocation concealment, ensuring that outcomes assessment is blinded (and reporting it as such) and retaining participants for followup assessment even when they drop out of an intervention. In addition, baseline comparability between groups could not be assured for quite a few of the excluded trials, particularly small trials in which a difference between groups of only a few cases had a large impact on the apparent comparability of the study groups. Given that high attrition may be very difficult to avoid in the high-risk populations targeted by many of the included trials, funders may want to consider recognizing that higher followup assessment costs will be needed to avoid risk of bias due to attrition in this field.

The health system-level interventions in this review had limited applicability to health systems in the United States, especially since they involved enhancing home-visiting services, which are not routinely available in the United States. However, some home-visiting services are available in the United States, and these interventions also included other elements that would be relevant to U.S.-based settings, such as development of guidelines and clinical pathways, provider training, and web-based tools for assessment and feedback. Interventions designed for implementation in health care systems in the United States could involve training providers, developing clinical pathways, electronic medical records-based tools, and facilitated access to behavioral health specialists embedded in the primary care settings, for example, and may be promising and feasible for health care systems in the United States. Further research is needed on these types of interventions.

Another limitation of the evidence was the small number of trials examining several potentially valuable interventions, such as physical activity, infant sleep education, in-hospital PND education with followup, and peer counseling. Many of these trials were conducted outside of the United States, often with fewer than 50 women per treatment arm. Moderate- to large-scale trials of these promising interventions conducted in the United States are needed. Similarly, larger-scale effectiveness trials of CBT and IPT approaches are needed to explore the degree to which these interventions can be scaled up, as well as their applicability to lower risk, more general primary populations. Although several of the counseling trials targeted black and Latino women, more information is needed on the effects of interventions in racial and ethnic minority patients, particularly as interventions are scaled up for broader dissemination.

Trials of behavior-based interventions did not report on harms directly, although quite a few did report on acceptability or satisfaction with care. Harms and acceptability are very important to consider and should be routinely reported, both among participants who engage in the intervention and those who do not. Also, the satisfaction with and impact of the interventions on primary care clinicians would be valuable to understand for interventions with connections to primary care.

More research is also needed on the use of antidepressants and dietary supplements in the role of preventing PND. We found only two small trials of antidepressants, and one of these was an older generation medication (nortriptyline, a tricyclic antidepressant). Trials of antidepressants should include very close monitoring, given some cases of conversion to mania and hypomania in the included studies. For individuals at very high risk, such as those with a previous history of PND, antidepressants may be a valuable tool for the prevention of PND and are feasible for implementation in primary care settings. While included evidence did not support the use of omega-3 fatty acids, other supplements such as selenium and vitamin D may be considered. We found one small trial of selenium supplementation starting in the first trimester of pregnancy in a general-risk population that found lower postpartum EPDS scores with selenium, at up to 8 weeks postpartum.^126^ This study was not included in our review because it was conducted in Iran and had followup on less than 50 percent of the randomized participants; nevertheless, the findings warrant further exploration. Cohort studies have found associations between lower serum vitamin D levels^127^ and dietary vitamin D intake^128^ during pregnancy and elevated EPDS scores. One of these found a dose-response relationship: the odds of scoring high on the EPDS were highest in the women with the lowest serum vitamin D. Together these studies suggest a possible role for vitamin D in PND prevention. Further exploration of antidepressants, selenium, and vitamin D is needed.

Another concern with the included evidence was the relatively larger effect in the analysis of dichotomous depression status compared with continuous symptom severity scores. While most trials that reported statistically significant improvement in symptom severity also reported improved depression status results, several trials showed benefits for depression status but not for depression severity. However, in all of these cases the depression status variable was either incidence or prevalence, which we believe to be a more reliable outcome than symptom severity. Incidence and prevalence are based on clinical interviews, allowing opportunities for probing and clarification, which we believe may enhance the reliability of the outcome.

Another important deficit in the literature is a lack of good information on the best way to identify persons who are at risk of PND. Measures of depression symptoms, such as the EPDS, likely provide the most direct association with future PND; however, evidence on whether and how to incorporate other risk factors is needed. Relatedly, a better understanding is needed on who is most likely to benefit from these preventive interventions and how they are best identified.

Ongoing studies are listed in Appendix I.

## Conclusion

Counseling-based interventions can be effective in preventing PND, although most evidence was limited to women at increased risk for PND. In addition, a variety of other intervention approaches, such as supportive and educational approaches, provided some evidence of effectiveness but lacked robust evidence bases. There was some evidence that omega-3 fatty acids and post-delivery debriefing interventions were not effective in reducing the risk of PND. Given the USPSTF recommendation to screen adults for depression, many pregnant and postpartum individuals in the United States are undoubtedly identified with symptoms of depression who do not meet criteria for depression; offering preventive CBT and IPT interventions would likely reduce the risk of these individuals developing depressive disorders, particularly those with low socioeconomic status.