# Chapter 3 Results

## Literature Search

We reviewed 1036 abstracts and 247 full-text articles (Appendix A Figure 2), and included 50 trials (8 good-quality, 42 fair-quality) that reported benefits or harms of an intervention to prevent PND, reported in 64 publications. The lists of included studies and excluded studies (with reasons for exclusion) are available in Appendix C and Appendix D, respectively.

## Summary of Results

We identified 50 trials (N=22,385) that met our inclusion criteria (Table 1; Appendix F Table 1 for alphabetical listing; Tables 2 and 3 for summary of study and intervention characteristics). Across all intervention types, the risk of PND was reduced by 27 percent (pooled RR=0.73 [95% CI, 0.64 to 0.82], k=42, n=17,411, I^2^=49%, Figure 1 and Table 4), and by an even larger amount when debriefing and omega-3 fatty acid interventions, which had evidence that they were not effective, were excluded (pooled RR=0.69 [95% CI, 0.61 to 0.78], k=38, n=15,003, I^2^=38%, Figure 2). Counseling interventions were the most widely studied approach; they reduced the likelihood of PND by 39 percent (pooled RR=0.61 [95% CI, 0.47 to 0.78], k=17, n=3094, I^2^=39%, Figure 3, Appendix E Figure 1, Table 4). The absolute reduction in the risk of PND was highly variable across studies, due to both variability in population risk and the fact that some trials reported depression diagnosis while others reported the proportion with high symptom severity scale scores (which may or may not indicate depression diagnosis). Two approaches, the CBT-based “Mothers and Babies” program and an IPT-based ROSE program, were studied in four and five trials, respectively. All nine of these trials were conducted in the United States, targeting high-risk women (e.g., primarily low-income and with a history or of depression or current depression symptoms), including a substantial proportion of Black and Latina participants. Pooled effects for these CBT and IPT interventions were even larger than the overall results for counseling interventions (but with overlapping confidence intervals). Health system and physical activity interventions showed similar pooled effects to the counseling interventions, but pooled effects were not statistically significant when using a method appropriate for pooling small numbers of trials (Figure 3, Appendix E Figure 1, Table 4). In addition, none of the three health system interventions were conducted in the United States, so applicability to the United States may be limited. The three physical activity interventions were also conducted outside the United States and the total number of participants was small (combined n randomized=1200). A few other behavior-based interventions showed promising results; however, few showed statistically significant group differences and even fewer have been replicated (Figure 4 and Appendix E Figure 2). None of the behavior-based interventions reported on harms specifically, but there was no pattern of negative impact across a wide range of outcomes, based on group means. There was evidence that debriefing interventions and omega-3 fatty acids (particularly docosahexaenoic acid [DHA]) are not effective in preventing PND (Figure 5 and Appendix E Figure 3). In two studies of prophylactic use of antidepressants initiated immediately after childbirth, sertraline showed a statistically significant benefit at 20 weeks postpartum in one very small study (n analyzed=22), but with an increased risk of side effects (e.g., dizziness, drowsiness). There was no benefit of nortriptyline use. Combining all intervention types, larger effects were associated with smaller studies, interventions that explicitly targeted depression, and studies that were limited to women with a history of depression and/or with symptoms of depression at baseline.

Figure 1 Forest Plot of Depression Incidence, Prevalence, or Exceeding a Symptom Cut-Off, Sorted by Followup Time

*Study-reported adjusted analyses were statistically significant, although effect size shown in the forest plot, based on unadjusted percentages, is not statistically significant.

**Study-reported adjusted analysis was not statistically significant, although effect size shown in the forest plot, based on unadjusted data, is statistically significant.

Note: For followup time, “g” indicates during gestation and “p” indicates postpartum; thus, for example, g37=37 weeks’ gestation and p12=12 weeks postpartum

Abbreviations: CBT= Cognitive-behavioral therapy; CI = Confidence interval; DHA = Docosahexaenoic Acid; Edu = Education; EPA = Eicosapentaenoic acid; G = gestational period (weeks); IPT = interpersonal therapy; Mgmt = management; NR = Not reported; P = postpartum period (weeks); PA = Physical activity; PPD = Postpartum depression; RR = Risk ratio; Tourne = A psychosomatic humanist group intervention developed by Dr. Claude-Emile Tourne

This figure is a forest plot of depression incidence, prevalence, or exceeding a symptom cut-off, sorted by followup time.

Figure 2 Summary of Pooled Effects by Intervention Type and for Subgroup and Sensitivity Analyses

*Excluded omega-3 fatty acid and debriefing interventions

Abbreviations: CBT= Cognitive-behavioral therapy; CG = control group; CI = Confidence interval; DL = DerSimonian and Laird; I2 = I squared; IG = intervention group; IPT = interpersonal therapy; Prev = Prevalence; REML = Restricted maximum likelihood; RR = Risk ratio; Sx/hx = symptoms/history; USA = United States

This figure is a forest plot showing a summary of pooled effects by intervention type and for subgroup and sensitivity analyses.

Figure 3 Forest Plot of Depression Incidence, Prevalence, or Exceeding a Symptom Cut-Off for Counseling, Health System, and Physical Activity Interventions, Sorted by Followup Time

**Study-reported adjusted analysis was not statistically significant, although effect size shown in the forest plot, based on unadjusted data, is statistically significant.

Note: For followup time, “g” indicates during gestation and “p” indicates postpartum; thus, for example, g37=37 weeks’ gestation and p12=12 weeks postpartum

Abbreviations: CBT= Cognitive-behavioral therapy; CES-D = Center for Epidemiologic Studies Depression Scale; CG = Confidence interval; CI = Confidence interval; EPDS = Edinburgh Postnatal Depression Scale; G = gestational period (weeks); IG = Intervention group; IPT = interpersonal therapy; LQ = Leverton Questionnaire; MT = Mindfulness Therapy; NR = Not reported; P = postpartum period (weeks); PA = Physical activity; Prev = Prevalence; RR = Risk ratio; Tourne = A psychosomatic humanist group intervention developed by Dr. Claude-Emile Tourne

This figure is a forest plot of depression incidence, prevalence, or exceeding a symptom cut-off for counseling, health system, and physical activity interventions, sorted by followup time.

Figure 4 Forest Plot of Depression Incidence, Prevalence, or Exceeding a Symptom Cut-Off for Other Behavior-Based Interventions, Sorted by Followup Time

*Study-reported adjusted analyses were statistically significant, although effect size shown in the forest plot, based on unadjusted percentages, is not statistically significant.

Note: For followup time, “g” indicates during gestation and “p” indicates postpartum; thus, for example, g37=37 weeks’ gestation and p12=12 weeks postpartum

Abbreviations: BDI = Beck’s Depression Inventory; CG = Confidence interval; CI = Confidence interval; EPDS = Edinburgh Postnatal Depression Scale IG = Intervention group; Mgmt = Management; P = postpartum period (weeks); PHQ = Patient Health Questionnaire; PPD = Postpartum period; Prev = Prevalence; RR = Risk ratio

This figure is a forest plot of depression incidence, prevalence, or exceeding a symptom cut-off for other behavior-based interventions, sorted by followup time.

Figure 5 Forest Plot of Depression Incidence, Prevalence, or Exceeding a Symptom Cut-Off for Antidepressants and Supplements, Sorted by Followup Time

Note: For followup time, “g” indicates during gestation and “p” indicates postpartum; thus, for example, g37=37 weeks’ gestation and p12=12 weeks postpartum

Abbreviations: CG = Confidence interval; CI = Confidence interval; DHA = Docosahexaenoic Acid; EPA = Eicosapentaenoic acid; IG = Intervention group; RR = Risk ratio

This figure is a forest plot of depression incidence, prevalence, or exceeding a symptom cut-off for antidepressants and supplements, sorted by followup time.

Table 1 Characteristics of Included Studies, by Intervention Type

Intervention Type (Approach) | Author, Year Quality Country | N Rand (% FU)^*^ | Population | Basis for population selection^†^ (Excluded current depression) | Age group | # Sessions (hrs) | Intervention explicitly depression-focused? | Intervention Initiated^‡^ (Perinatal phase spanned by intervention) | Intervention | Format Delivery | Provider
Counseling (CBT) | Brugha, 2000^53^ Fair UK | 209 (90.9) | Primiparous, 12–20 weeks’ gestation, at increased risk of PND | Depression (NR) | Adults & Adolescents | 8 (14) | Yes | g16 (Pregnant) | Eight 2-hour weekly CBT antenatal group classes | Group, Couples In-person, Print | Nurse, OT
Counseling (CBT) | Le, 2011^84^ Fair US | 217 (80.2) | Latinas, ≤24 weeks gestation, at high risk for depression (CESD ≥16 or personal or family history of depression) | Depression (Yes) | Adults | 11 (16) | Yes | g14 (Both) | Eight 120-min weekly group CBT Mothers and Babies Course prenatal sessions and three individual postpartum booster sessions | Individual, Group In-person | Research Staff
Counseling (CBT) | Milgrom, 2011^97^ Fair AUS | 143 (62.2) | 20–32 weeks’ gestation | None (No) | Adults | 8 (4) | Yes | g25 (Both) | Eight 30-min phone counseling sessions with self-guided CBT workbook | Individual Phone, Print | Psychologist
Counseling (CBT) | Munoz, 2007^83^ Fair US | 41 (NR) | Low-income women, primarily immigrant Latina, 12–32 weeks’ gestation, meeting high-risk criteria for MDE | Depression (Yes) | Adults | 16 (NR) | Yes | g16 (Both) | 12 weekly CBT prenatal mood management sessions and 4 postpartum booster sessions | Group In-person | Psychologist
Counseling (CBT) | Tandon, 2011^79^ Fair US | 98 (60.2) | Low income, pregnant and up to 26-weeks postpartum, elevated depressive symptoms (CES-D ≥16) and/or lifetime depressive episode (but were not currently exhibiting a depressive episode) | Depression (Yes) | Adults | 11 (12) | Yes | p13 (Unclear/variable) | Six 120-min CBT group sessions and five 5–10 minute during one-on-one home visits | Individual, Group In-person | Psychologist, clinical social worker
Counseling (CBT) | Tandon, 2014^38^ Fair US | 120 (97.4) | Low income, pregnant and up to 26 weeks postpartum, elevated depressive symptoms (CES-D ≥ 16) and/or lifetime depressive episode (but not currently exhibiting a depressive episode) | Depression (Yes) | Adults | 13 (16) | Yes | p13 (Unclear/variable) | Six 120-min group CBT Mothers and Babies Course sessions, five 5–10 min home visit reinforcement, two booster sessions | Individual, Group In-person | Psychologist, clinical social worker
Counseling (CBT, IPT) | Kozinsky, 2012^93^ Fair HU | 1438 (97.6) | Hungarian women, 25 weeks’ gestation, only abstracted non-depressed subgroup, LQ≤11 | None (Yes) | Adults | 4 (12) | Yes | g25 (Pregnant) | Four 3-hour group IPT/CBT sessions | Group, Couples In-person | Psychiatrist, health visitors with training in psychiatry
Counseling (CBT, MT) | Dimidjian, 2016^90^ Fair US | 86 (80.2) | Pregnant adult women, up to 32 weeks’ gestation, history of depression | Depression (Yes) | Adults | 8 (16) | Yes | g16 (Pregnant) | Eight weekly, 2-hour sessions of mindfulness-based cognitive therapy for perinatal depression | Group In-person | Psychologist, Research Staff
Counseling (Couples) | Feinberg, 2008^91^ Fair US | 169 (89.9) | Heterosexual couples living together expecting first child | None (No) | Adults | 8 (NR) | No | g22.9 (Both) | Four prenatal psychoeducational group sessions, followed by 4 postnatal group sessions promoting positive joint parenting | Group, Couples In-person | NR
Counseling (IPT) | Gorman, 1997^81^ Fair US | 45 (86.6) | Pregnant women in third trimester, high risk based on personal or family history of depression, low support, or life events | Both (No) | Both | 5 (NR) | Yes | g32 (Pregnant) | Five psychoeducation & IPT sessions during late pregnancy and first four weeks postpartum. | Individual In-person | NR
Counseling (IPT) | Leung, 2012^94^ Fair HKG | 156 (93) | 14–32 weeks’ gestation | None (Yes) | Adults | 4 (6) | Yes | g20.2 (Pregnant) | Four 90-min group sessions targeting interpersonal issues and intergenerational conflict | Group In-person | NR
Counseling (IPT) | Phipps, 2013^41^ Good US | 106 (94) | Adolescents (age ≤17 years at conception), <25 weeks’ gestation, no current affective disorder. | Other (Yes) | Adolescents | 6 (6) | Yes | g20.5 (Both) | Five 60-min prenatal IPT sessions (delivered in group and individual format), one postpartum session delivered in hospital after delivery | Individual, Group In-person, Video | NR
Counseling (IPT) | Zlotnick, 2001^86^ Fair US | 37 (94.6) | Women receiving public assistance, 20–32 weeks’ gestation with at least one predictor of postpartum depression | Both (Yes) | Adults | 4 (4) | Yes | g26 (Pregnant) | Four 60-min interpersonal therapy-oriented weekly group sessions | Group In-person | NR
Counseling (IPT) | Zlotnick, 2006^87^ Fair US | 99 (86.9) | Women on public assistance, 23–32 weeks’ gestation and at risk for postpartum depression but not currently depressed | Both (Yes) | Adults | 5 (5) | Yes | g27.5 (Both) | Four 6-minute prenatal group IPT sessions and one 50-min postpartum individual booster session. | Individual, Group In-person | Nurse
Counseling (IPT) | Zlotnick, 2011^88^ Fair US | 54 (85.2) | 18 to 40 years old with past-year intimate partner violence | Other (Yes) | Adults | 5 (5) | Yes | g21.3 (Pregnant) | Four weekly 60-min prenatal individual IPT sessions followed by one 60-min booster sessions within 2 weeks of delivery | Individual In-person | Research Staff
Counseling (IPT) | Zlotnick, 2016^42^ Good US | 205 (86.3) | Receiving public assistance, 20–35 weeks’ gestation, ≥27 on the CSQ and no current depression | Both (Yes) | Adults | 5 (7) | Yes | g27.1 (Both) | Four weekly 90-min IPT prenatal group sessions and one 50-min individual postnatal session | Individual, Group In-person | Nurse, Research Staff
Counseling (MT) | Woolhouse, 2014^92^ Fair AUS | 32 (71.8) | 11–33 weeks’ gestation | None (No) | Adults | 6 (12) | No | g19 (Pregnant) | Six 120-min weekly mindfulness-based group therapy sessions | Group In-person | Psychologist, Psychiatrist
Counseling (NR) | Cooper, 2015^95^ Fair UK | 301 (88.3) | Primiparous women scoring at risk of developing PND | Both (No) | Adults | 11 (NR) | No | p30 (Postpartum) | 11 home visits providing supportive counseling, parenting skills, education about infant development and behavior | Individual In-person | Nurse, Midwife
Counseling (NR) | Dugravier, 2013^72^ Fair FRA | 367 (75.7) | First-time mothers age <26 and high-risk based on SES, 12–27 weeks gestation | Other (No) | Adults | 14 (NR) | Yes | g19.5 (Both) | 14 home visits to support effective parenting skills and use of health, community, and social support systems | Individual In-person | Psychologist
Counseling (Tourne) | Ortiz Collado, 2014^89^ Fair FRA, ESP | 184 (69) | Low SES women, ≤20 weeks’ gestation, at moderate to high risk of PND (≥3 on risk rating scale) | Both (Yes) | Adults | 20 (23) | Yes | g12 (Pregnant) | Ten 135-min couples’ psychosomatic humanist group sessions, ten followup phone calls | Group In-person, Phone | Midwife
Health System (Home visitor) | Brugha, 2011^66^ Fair UK | 2824 (79.4) | 6 weeks’ postpartum, <12 on EPDS | None (Yes) | Adults | NR (NR) | Yes | p6 (Postpartum) | Health visitor trained in systematic assessment of depressive symptoms | In-person Home visitor | Nurse
Health System (Postpartum care) | MacArthur, 2002^73^ Fair UK | 2064 (73) | Postpartum | None (No) | Both | NR (3) | Yes | p0 (Postpartum) | Postpartum care delivered by midwives with additional training in depression screening and management | Individual In-person | Midwife
Health System (Prenatal care) | Fontein-Kuipers, 2016^74^ Fair NLD | 433 (79.2) | 4–14 weeks’ gestation | None (No) | Adults | 1 (NR) | Yes | g7 (Pregnant) | Midwives specially trained in prenatal care plus one computer-based assessment session with personalized feedback for pregnant women | Individual In-person, Web | Midwife
PA (PA) | Norman, 2010^101^ Fair AUS | 161 (80.7) | 6–10 weeks postpartum, ready for discharge from the postnatal ward | None (No) | Adults | 8 (12) | No | p8 (Postpartum) | Eight 60-min group exercise sessions followed by 30-min education sessions | Group In-person, Print | Midwife, PT, Psychologist, Dietician Speech pathologist
PA (PA) | Perales, 2015^100^ Good ESP | 184 (90.7) | 9–12 weeks’ gestation | None (No) | Adults | 90 (90) | No | g10.5 (Both) | Ninety 60 min group exercise sessions (three times per week for 30 weeks) | Group In-person | Physician, Fitness specialist
PA (PA) | Songoygard, 2012^99^ Fair NOR | 855 (84.1) | 18 weeks’ gestation | None (No) | Adults | 12 (12) | No | g18 (Pregnant) | Twelve 60-min group exercise sessions with instructions for home exercise and dietary advice | Individual, Group In-person | PT
Education (PND Booklet) | Heh, 2003^102^ Fair TW | 70 (100) | First-time mothers, 4–6 weeks postpartum, EDPS ≥10 | Depression (No) | Adults | 1 (NR) | Yes | p5 (Postpartum) | One educational booklet on PND received 6 weeks postpartum | Individual Print | Self
Education (PND Edu) | Hayes, 2001^103^ Fair AUS | 206 (91.2) | First-time mothers, 12–28 weeks’ gestation | None (Yes) | Adults | 1 (NR) | Yes | g20 (Pregnant) | One PND informational session reviewing an educational package with an experienced midwife | Individual, Family In-person | Midwife
Education (PND Edu) | Howell, 2012^75^ Fair US | 540 (78) | Black/African American or Hispanic/Latino postpartum women, 0–3 days postpartum | None (No) | Adults | 2 (0) | Yes | p0 (Postpartum) | 15 min in person PND educational session in the hospital post-delivery and followup phone call | Individual In-person, Phone | Social worker
Education (PND Edu) | Howell, 2014^76^ Fair US | 540 (86) | White or Asian women, 0–2 days postpartum | None (No) | Adults | 2 (0) | Yes | p0 (Postpartum) | 15 min in person PND educational session in the hospital post-delivery and follow-up phone call | Individual In-person, Phone | Social worker
Education (Prenatal Gen Edu) | Fisher, 2016^80^ Good AUS | 400 (91) | Primiparous women, <6 weeks postpartum | None (No) | Both | 1 (6) | No | p6 (Postpartum) | Single 6-hour psychoeducational group session for couples that are first-time parents | Couples In-person, Print | Nurse
Education (Prenatal PND module) | Maimburg, 2015^104^ Good DNK | 1193 (90) | Nulliparous women, 10–22 weeks’ gestation | None (No) | Adults | 3 (9) | No | g24 (Pregnant) | Three 3-hour prenatal group education sessions, including a didactic session on PND | Group In-person | Midwife
Support (Case Mgmt) | Kenyon, 2016^68^ Good UK | 1324 (92) | Nulliparous women, <28 weeks’ gestation, with social risk factors | Other (No) | Both | NR (NR) | No | g13 (Both) | Case management by lay pregnancy outreach worker, including support and advice (sessions NR) | Individual In-person, Phone, Email or Text | Peer
Support (Community referral) | Wiggins, 2004^67^ Good UK | 731 (90) | Living in economically deprived districts, ≤10 weeks postpartum | None (No) | Adults | 7 (10) | Yes | p9 (Postpartum) | Referral to community support organizations for their standard service; services varied by community organization. | Group In-person, Phone | Community group
Support (Home visitor) | Morrell, 2000^82^ Fair UK | 623 (79.1) | At delivery | None (No) | Both | 10 (30) | No | p0 (Postpartum) | Ten 3-hour support worker visits per day over first 28 days postpartum, providing practical and emotional support | Individual In-person | Midwife
Support (Home visitor) | Wiggins, 2004^67^ Good UK | 731 (90) | Living in economically deprived districts, ≤10 weeks postpartum | None (No) | Adults | 7 (10) | No | p9 (Postpartum) | Up to 22 in person supportive listening home visits | Individual In-person | Health visitor
Support (Peer support) | Dennis, 2003^105^ Fair CAN | 42 (97.6) | 8–12 weeks postpartum, at high-risk for postpartum depression (EPDS >9) | Depression (No) | Adults | 5 (3) | Yes | p10 (Postpartum) | Telephone based peer support, length or number of sessions at discretion of peer volunteers. | Individual Phone | Peer
Support (Peer support) | Dennis, 2009^77^ Fair CAN | 701 (85.6) | New mothers, 2 weeks postpartum, high risk of PND (EPDS >9) | Depression (No) | Adults | 9 (2) | Yes | p2 (Postpartum) | Minimum of 4 peer phone support contacts | Individual Phone | Peer
Support (Support group) | Reid, 2002^106^ Fair UK | 1004 (73) | Primiparous women, 34–37 weeks’ gestation | None (No) | Adults | NR | No | p35.5 (Postpartum) | Weekly 2-hour support nondirective group sessions (only 18% attended any meetings) | Group In-person, Print | Midwife
Support (Support group) | Stamp, 1995^107^ Fair AUS | 144 (87) | <24 weeks’ gestation, risk of postnatal depression | Both (No) | Adults | 3 (NR) | No | g14 (Pregnant) | Two antenatal nondirective, practical, and supportive group sessions held at 32- and 36-weeks’ gestation and at 6-weeks postpartum | Group In-person | Midwife
Sleep (Sleep) | Hiscock, 2014^78^ Fair AUS | 770 (71) | Primary caregiver of newborn infants 7–10 days postpartum | None (No) | Adults | 2 (NR) | No | p4 (Postpartum) | One mailed information packet focused on infant crying and sleeping, and parent self-care; One telephone call (min NR); One 1.5-hour group session | Group, Family In-person, Phone, Print, Video | Nurse, Psychologist
Sleep (Sleep) | Werner, 2016^85^ Fair US | 54 (64.8) | 28–38 weeks’ gestation | Both (No) | Adults | 4 (NR) | No | p36 (Both) | Three in-person sessions plus 1 phone session teaching skills to manage infant crying and promote sleep, plus psychological support | Individual In-person, Phone | Psychologist
Sleep (Other) | Hiscock, 2002^109^ Fair AUS | 156 (98.7) | Women with infants 6–12 months of age reporting infant sleep problems, not receiving treatment for postnatal depression | Both (No) | Adults | 3 (NR) | No | p37 (Postpartum) | 3 private consultation sessions to promote infant sleep | Individual In-person | Physician
Yoga (Yoga) | Davis, 2015^110^ Fair US | 46 (87.0) | Women with elevated anxiety symptoms, up to 28 weeks’ gestation; EPDS ≥ 9 | Both (No) | Adults | 8 (10) | No | g20.8 (Pregnant) | Eight 75-min yoga sessions | Individual, Group In-person, Video | Fitness instructor
Debrief (Debrief) | Priest, 2003^111^ Fair AUS | 1745 (80.3) | 1 to 3 days post-delivery | None (No) | Adults | 1 (1) | No | p0 (Postpartum) | One 15 to 60 min standardized debriefing session in hospital | Individual In-person | Midwife
Debrief (Debrief) | Small, 2000^44^ Fair AUS | 1041 (88) | Operative delivery, at least 1 day postpartum | Other (No) | Both | 1 (1) | No | p0 (Postpartum) | One debriefing session, up to 60 min, with midwife | Individual In-person | Midwife
Other (Expressive writing) | Di Blasio, 2015^112^ Fair ITA | 120 (94.2) | Women who had given birth in past few days | None (No) | Adults | 2 (1) | No | p0 (Postpartum) | Two, 15–20 min expressive writing sessions in 1 day. | Individual Print | Self
Antidepressant (Nortriptyline) | Wisner, 2001^46^ Fair US | 58 (92.2) | 35 weeks’ gestation or less; history of postpartum-onset MDD in the previous 5 years but no current treatment for depression | Depression (Yes) | Adults | 0 (0) | Yes | p0 (Postpartum) | Nortriptyline | Individual Pharm | Nurse, Psychiatrist, Research Staff
Antidepressant (Sertraline) | Wisner, 2004^45^ Fair US | 22 (88.0) | 35 weeks’ gestation or less; history of postpartum-onset MDD in the previous 5 years but no current treatment for depression | Depression (Yes) | Adults | 0 (0) | Yes | p0 (Postpartum) | Sertraline | Individual Pharm | Physician, Psychiatrist
Supplements (DHA Supplementation) | Llorente, 2003^51^ Fair US | 101 (64.8) | Women planning on breastfeeding their infants exclusively for at least 4 months within 1 week postpartum | None (No) | Adults | NA (NR) | Yes | p1 (Postpartum) | DHA Supplementation | Individual Pharm | NR
Supplements (DHA-rich fish oil) | Mozurkewich, 2013^50^ Good US | 126 (93.4) | 12–20 weeks’ gestation, EPDS 9–19 or history of depression | Depression (Yes) | Adults | 4 (NR) | Yes | g16 (Both) | DHA-rich fish oil supplementation | Individual Pharm | Physician
Supplements (EPA-rich fish oil) | Mozurkewich, 2013^50^ Good US | 126 (93.4) | 12–20 weeks’ gestation, EPDS 9–19 or history of depression | Depression (Yes) | Adults | 4 (NR) | Yes | g16 (Both) | EPA-rich fish oil supplementation | Individual Pharm | Physician

* Followup at the assessment closest to 6 months postpartum

† Both = participants included if they had depression-related or non-depression-related risk factors; Depression = depression history or symptoms at baseline; None = not selected for increased risk of PND; Other = non-depression-related risk factors (e.g., socioeconomic, social)

‡ Estimated average week that the intervention was initiated; “g” indicates during gestation and “p” indicates postpartum; thus, for example, g37=37 weeks’ gestation and p12=12 weeks postpartum

Abbreviations: AUS = Australia; CAN = Canada; CBT= Cognitive-behavioral therapy; CES-D = Center for Epidemiologic Studies Depression Scale; CSQ = Cognitive Style Questionnaire; DHA = Docosahexaenoic Acid; DNK = Denmark; EPA = Eicosapentaenoic acid; EPDS = Edinburgh Postnatal Depression Scale; ESP = Spain; FRA = France; FU = followup; G = gestational period (weeks); HKG = Hong Kong; Hrs = hours; HU = Hungary; IPT = interpersonal therapy; ITA = Italy; LQ = Leverton Questionnaire; MDD = Major Depressive Disorder; MDE = Major Depressive Episode; Min = Minute; MT = Mindfulness Therapy; NA = Not applicable; NLD = New Zealand; NOR = Norway; NR = Not reported; P = postpartum period (weeks); PA = Physical activity; PND = Postnatal depression; Rand = randomized; SES = socioeconomic status; UK = United Kingdom; US = United States

Table 2 Summary of Study Characteristics, by Intervention Type

Intervention Category | N Randomized (k) | Good quality, k (%) | Conducted in the US, k (%) | IG initiated during pregnancy, k (%) | Adults only, k (%) | Screening/Outreach^*^, k (%) | Pop Selection Depression only, k (%) | Pop Unselected, k (%) | Excluded Dep dx/high sx, k (%) | Majority non-white, k (%) | Primarily low-SES participants, k (%)
Overall | 22,385 (50) | 8 (16) | 20 (40) | 26 (52) | 42 (84) | 42 (84) | 12 (24) | 23 (46) | 20 (40) | 11 (22) | 13 (26)
Counseling | 4107 (20) | 2 (10) | 12 (60) | 17 (85) | 17 (85) | 17 (85) | 6 (30) | 5 (25) | 13 (65) | 8 (40) | 10 (50)
Health System | 5321 (3) | 0 (0) | 0 (0) | 1 (33.3) | 2 (66.7) | 3 (100) | 0 (0) | 3 (100) | 1 (33.3) | 0 (0) | 0 (0)
PA | 1200 (3) | 1 (33.3) | 0 (0) | 2 (66.7) | 3 (100) | 3 (100) | 0 (0) | 3 (100) | 0 (0) | 0 (0) | 0 (0)
Education | 2949 (6) | 2 (33.3) | 2 (33.3) | 2 (33.3) | 5 (83.3) | 6 (100) | 1 (16.7) | 5 (83.3) | 1 (16.7) | 2 (33.3) | 1 (16.7)
Support | 4569 (7) | 2 (28.6) | 0 (0) | 2 (28.6) | 5 (71.4) | 7 (100) | 2 (28.6) | 3 (42.9) | 2 (28.6) | 0 (0) | 2 (28.6)
Sleep | 980 (3) | 0 (0) | 1 (33.3) | 0 (0) | 3 (100) | 2 (66.7) | 0 (0) | 1 (33.3) | 0 (0) | 1 (33.3) | 0 (0)
Yoga | 46 (1) | 0 (0) | 1 (100) | 1 (100) | 1 (100) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 0 (0)
Debriefing | 2786 (2) | 0 (0) | 0 (0) | 0 (0) | 1 (50) | 2 (100) | 0 (0) | 1 (50) | 0 (0) | 0 (0) | 0 (0)
Expressive Writing | 120 (1) | 0 (0) | 0 (0) | 0 (0) | 1 (100) | 1 (100) | 0 (0) | 1 (100) | 0 (0) | 0 (0) | 0 (0)
AD | 80 (2) | 0 (0) | 2 (100) | 0 (0) | 2 (100) | 1 (50) | 2 (100) | 0 (0) | 2 (100) | 0 (0) | 0 (0)
Omega-3 fatty acids | 227 (2) | 1 (50) | 2 (100) | 1 (50) | 2 (100) | 0 (0) | 1 (50) | 1 (50) | 1 (50) | 0 (0) | 0 (0)

* Number recruited via screening or outreach versus volunteer opt-in

Abbreviations: AD = Antidepressants; Dx = Diagnosis; IG = Intervention group; K = number of studies; PA = Physical activity; POP = Population; DEP = Depression; SES = socioeconomic status; Sx = Symptoms; US = United States

Table 3 Summary of Intervention Characteristics, by Intervention Type

Intervention Category | Total k | Depressionfocused intervention, k (%) | Parenting/attachment focus, k (%) | Conducted in primary care/OB-GYN, k (%) | Involved group sessions, k (%) | Involved individual sessions, k (%) | Involved home visits, k (%) | Weeks duration, median (range) | Sessions, median (range) | Hours, median (range)
Overall | 52 | 32 (61.5) | 6 (11.5) | 10 (19.2) | 24 (46.2) | 35 (67.3) | 8 (15.4) | -- | -- | --
Counseling | 20 | 17 (85) | 4 (20) | 3 (15) | 15 (75) | 11 (55) | 4 (20) | 8 (4–70) | 8 (4–20) | 12 (4–23.3)
Health System | 3 | 3 (100) | 0 (0) | 1 (33.3) | 0 (0) | 3 (100) | 1 (33.3) | NA | NA | NA
PA | 3 | 0 (0) | 0 (0) | 0 (0) | 3 (100) | 1 (33.3) | 0 (0) | 12 (8–30) | 12 (8–90) | 12 (12–90)
Education | 6 | 4 (66.7) | 1 (16.7) | 2 (33.3) | 1 (16.7) | 4 (66.7) | 0 (0) | 0.14 (0.14–5) | 1 (1–3) | 0.5 (0.5–9)
Support | 8 | 2 (28.6) | 0 (0) | 0 (0) | 3 (37.5) | 5 (62.5) | 3 (37.5) | 14 (4–52) | 7 (3–10) | 2.9 (2.1–30)
Sleep | 3 | 0 (0) | 1 (33.3) | 1 (33.3) | 1 (33.3) | 2 (66.7) | 0 (0) | 12 (12–20) | 3 (2–4) | NR
Yoga | 1 | 0 (0) | 0 (0) | 0 (0) | 1 (100) | 1 (100) | 0 (0) | 8 (NA) | 8 (NA) | 10 (NA)
Debriefing | 2 | 0 (0) | 0 (0) | 0 (0) | 0 (0) | 2 (100) | 0 (0) | 0.14 (0.14) | 1 (1) | 0.7 (0.7–1)
Other: Expressive writing | 1 | 1 (100) | 0 (0) | 0 (0) | 0 (0) | 1 (100) | 0 (0) | -- | -- | --
AD | 2 | 2 (100) | 0 (0) | 1 (50) | 0 (0) | 2 (100) | 0 (0) | 20 (20) | NA | NA
Omega-3 fatty acids | 3 | 3 (100) | 0 (0) | 2 (66.7) | 0 (0) | 3 (100) | 0 (0) | 32 (16–32) | NA | NA

Abbreviations: AD = Antidepressants; OB-GYN = Obstetrics and gynecology; NA = Not applicable; PA = Physical activity

Table 4 Meta-Analysis Results Summary for the Outcome Depression Incidence, Prevalence, or Exceeding a Symptom Cut-Off

Subgroup of trials | Pooled RR | LCI | UCI | k | I^2^ | N | Tau
All included trials | 0.73 | 0.65 | 0.82 | 42 | 49 | 17,411 | 0.23
Counseling | 0.61 | 0.47 | 0.78 | 17 | 39 | 3094 | 0.29
Health System (DL) | 0.60 | 0.43 | 0.83 | 3 | 66 | 4738 | 0.23
Physical Activity (DL) | 0.54 | 0.33 | 0.87 | 3 | 0 | 1021 | 0.00
Health System (REML) | 0.58 | 0.22 | 1.53 | 3 | 66 | 4738 | 0.30
Physical Activity (REML) | 0.54 | 0.18 | 1.57 | 3 | 0 | 1021 | 0.00
Omega-3 fatty acids | 1.71 | 0.70 | 4.17 | 3 | 0 | 204 | 0.00
Debriefing | 1.04 | 0.88 | 1.22 | 2 | 27 | 2662 | 0.07
Drop Omega-3, Debriefing | 0.69 | 0.61 | 0.78 | 38 | 33 | 15,003 | 0.19
Conducted in the USA^*^ | 0.54 | 0.43 | 0.69 | 15 | 0 | 1875 | 0.00
Conducted outside the USA^*^ | 0.74 | 0.64 | 0.84 | 23 | 33 | 13,128 | 0.19
Unselected participants^*^ | 0.75 | 0.65 | 0.86 | 18 | 41 | 12,278 | 0.18
Selected participants (on any basis)^*^ | 0.60 | 0.50 | 0.72 | 20 | 10 | 2725 | 0.13
Selected participants (on any basis)^*^, counseling trials only | 0.55 | 0.43 | 0.68 | 14 | 0 | 1411 | 0.00
Selected participants for depression symptoms or history^*^ | 0.50 | 0.38 | 0.66 | 10 | 0 | 786 | 0.00
Intervention during pregnancy ONLY^*^ | 0.64 | 0.47 | 0.87 | 11 | 60 | 4564 | 0.37
Intervention during postpartum ONLY^*^ | 0.76 | 0.67 | 0.85 | 16 | 8 | 8,551 | 0.07
Intervention spans both pregnancy and postpartum^*^ | 0.61 | 0.49 | 0.76 | 9 | 0 | 1754 | 0.00
Any intervention components during pregnancy^*^ | 0.62 | 0.51 | 0.77 | 20 | 44 | 6318 | 0.28
Any interventions components postpartum^*^ | 0.73 | 0.65 | 0.81 | 25 | 9 | 10305 | 0.08
1–3 month outcomes^*^ | 0.76 | 0.63 | 0.92 | 21 | 39 | 7349 | 0.24
>3–6 month outcomes^*^ | 0.69 | 0.58 | 0.81 | 19 | 24 | 8063 | 0.16
>6–12 month outcomes^*^ | 0.62 | 0.46 | 0.84 | 6 | 0 | 673 | 0.00
CBT interventions | 0.51 | 0.33 | 0.79 | 8 | 49 | 2128 | 0.41
CBT Moms and Babies Program | 0.47 | 0.26 | 0.84 | 4 | 0 | 325 | 0.00
IPT interventions | 0.71 | 0.5 | 1.00 | 8 | 42 | 2095 | 0.30
IPT ROSE Program | 0.50 | 0.32 | 0.80 | 5 | 12 | 464 | 0.19
Any dichotomous depression outcome | 0.73 | 0.65 | 0.82 | 42 | 49 | 17,411 | 0.23
Incidence outcome only | 0.63 | 0.45 | 0.89 | 15 | 55 | 2856 | 0.42
Incidence or prevalence outcomes only | 0.73 | 0.59 | 0.91 | 31 | 31 | 5081 | 0.27
Any dichotomous depression outcome^*^ | 0.69 | 0.61 | 0.78 | 38 | 33 | 15,003 | 0.19
Incidence outcome only^*^ | 0.50 | 0.38 | 0.66 | 11 | 0 | 907 | 0.00
Incidence or prevalence outcomes only^*^ | 0.56 | 0.44 | 0.72 | 16 | 0 | 1692 | 0.00

* Excluded Debriefing and Omega-3 fatty acid intervention trials

Abbreviations: CBT = cognitive behavioral therapy; DL= Dersimonian & Laird model; IPT = interpersonal therapy; k = number of study arms in the meta-analysis; LCI = lower confidence interval; N = total number of participants analyzed in all studies included in the analysis; REML = restricted maximum likelihood model; RR = risk ratio; UCI = upper confidence interval

## Key Question 1 Do Interventions to Prevent Perinatal Depression Improve Health Outcomes in Pregnant or Postpartum Women or Their Children?

## Key Question 1a In Trials That Limit Enrollment to High-Risk Women, How Are Participants Identified as Being at High-Risk of Developing Perinatal Depression?

### Included Trials

All 50 included trials (n=22,385 randomized) reported on the benefits of an intervention to prevent PND (i.e., key question 1). See Table 1 (and Appendix F Table 1) for individual study characteristics and Table 2 for summary statistics, overall and by intervention type. Of these, 40 percent (20/50) were conducted in the United States, and most recruited women from primary care or obstetrics and gynecology (OB-GYN) practices (33/50 [66%]) or from other clinical settings (13/50 [26%]) such as in the hospital postdelivery, through electronic medical records, or in clinic/hospital-based childbirth education classes. Eight of the trials were rated as good-quality, and the remaining 42 were fair-quality; 27 were excluded due to poor quality. Among those that were rated as poor quality, 12 were excluded primarily for high or differential attrition, two for lack of baseline comparability between groups, one primarily because study interventionists conducted the outcomes assessments (among other more minor issues), and the others had multiple issues leading to an overall lack of confidence in the results (e.g., relatively high attrition, lack of information on a number of important fields, moderate levels of noncomparability of group at baseline, nonblinded outcomes assessment). Several of the trials excluded for quality appeared to be pilot studies that were primarily targeted at determining the feasibility of the interventions. Of the trials that were rated as fair-quality, the most common concerns were high (>10%) attrition, differential attrition between groups, and lack of assurance that that groups were comparable at baseline. Several had generally good methods but were graded down for high attrition.^66,^ ^72-78^ High retention may be very difficult to achieve in the high-risk populations targeted by some of these studies, but nevertheless it does compromise the strength of the results.

Trials were roughly evenly divided between whether they targeted pregnant (26/50 [52%]) or postpartum (22/50 [44%]) women, and two trials recruited women who were pregnant as well as those up to 26 weeks postpartum.^38,^ ^79^ Most trials (42/50 [84%]) were limited to women age 18 or older, but one^41^ targeted adolescents and seven included pregnant or postpartum women of any age (but did not report the proportion who were younger than 18).^44,^ ^53,^ ^68,^ ^73,^ ^80-82^ The weighted average age across all trials was 28.6 (range of average age at baseline across all studies was 16 to 34). Twenty-six of the trials (52%) selected women at increased risk for PND, such as having a personal or family history of depression (or PND), elevated depressive symptoms, or socioeconomic (e.g., low income, single/without partner, young, recent intimate partner violence) or mental health (elevated anxiety symptoms, history or significant negative life events) risk factors. Although the majority of participants in the included trials were non-Hispanic White (69% of all participants in trials that reported race/ethnicity), two trials were limited to Latina women^83,^ ^84^ and eight had majority Black and Latina samples.^38,^ ^41,^ ^42,^ ^79,^ ^85-88^ All of the trials with majority Black and Latina samples were conducted in the United States, representing half (10/20) of the trials conducted in this country. In addition, 26 percent (13/50) of the trials were primarily or entirely composed of economically disadvantaged women.^38,^ ^42,^ ^67,^ ^68,^ ^72,^ ^75,^ ^79,^ ^83,^ ^84,^ ^86-89^ See Appendix F Table 2 for detailed population characteristics of the included studies.

The trials assessed the impact of a wide range of intervention approaches, including counseling, health system-level interventions, physical activity, supportive interventions, education, infant sleep advice, birth-experience postpartum debriefing, expressive writing, yoga, omega-3 fatty acids, sertraline, and nortriptyline. Interventions are discussed in further detail under “Findings by Intervention Type.” See Table 3 for a summary of intervention characteristics, and Appendix F Tables 3 and 4 for detailed intervention characteristics by study.

### Overall Findings, Combining All Intervention Types

#### Depression Outcomes

Across all intervention approaches, most trials reported a dichotomous depression status outcome: depression incidence, depression prevalence, or the proportion of participants who scored above a prespecified cutoff on a continuous depression symptom severity scale such as the EPDS. Combining all three of these outcomes, the included interventions reduced the risk of PND by 27 percent (pooled RR=0.73 [95% CI, 0.65 to 0.82], k=42, n=17,411, I^2^=50%, Figure 1, Appendix F Table 5). Because there was a wide range of intervention approaches, separate effects were calculated for each intervention type. A summary of those results is shown in Figure 2 and Table 4, along with other subgroup and sensitivity analyses. The proportion with depression according to any of the dichotomous depression outcomes ranged from 0 to 40 percent in the intervention groups, compared with 1 to 69 percent in the control groups, with a median absolute risk difference of 4.8 percentage points (interquartile range [IQR] 13.1 to 0.4 percentage points favoring the intervention group). Across all possible timepoints, the proportion with depression among trials that reported major depressive disorder diagnosis based on a clinical interview ranged from 0 to 26 percent in the intervention groups versus 0 to 50 percent in the control groups (median absolute risk difference=8.5 [IQR 15.7 percentage points favoring the intervention group to 1.0 percentage points favoring the control group]). Continuous depression symptom severity outcomes were less likely to be reported and were also less likely to show statistically significant differences between groups (Figure 6, Appendix F Tables 6 and 7, see Appendix G for a list of depression symptom measurement instruments and their ranges and recommended cutoffs). Most studies that found statistically significant effects for depression symptoms also found between-group differences for depression status.

Figure 6 Forest Plot of Depression Symptom Scores, Grouped by Intervention Type

*Study-reported adjusted analyses were statistically significant, although effect size shown in the forest plot, based on unadjusted percentages, is not statistically significant.

Note: For followup time, “g” indicates during gestation and “p” indicates postpartum; thus, for example, g37=37 weeks’ gestation and p12=12 weeks postpartum

Abbreviations: BDI = Beck’s Depression Inventory; CBT= Cognitive-behavioral therapy; CG = Confidence interval; CI = Confidence interval; DHA = Docosahexaenoic Acid; EPA = Eicosapentaenoic acid; EPDS = Edinburgh Postnatal Depression Scale; G = gestational period (weeks); IG = Intervention group; IPT = interpersonal therapy; MT = Mindfulness therapy; NR = Not reported; P = postpartum period (weeks); PA = Physical activity; PPD = Postpartum period; SD = Standard deviation; WMD = Weighted mean difference

This figure is a forest plot of derpession symptom scores, grouped by intervention type.

#### Exploration of Heterogeneity in Effects

Because it was our primary outcome and the most commonly reported outcome, we conducted most analyses exploring effect heterogeneity using the outcome of depression status. Combining all intervention approaches, we found evidence of a small studies effect using Egger’s test (p=0.001, see Figure 7 for funnel plot). We also conducted meta-regression to explore the association of a wide range of study and intervention characteristics with effect size for the dichotomous depression outcomes. Larger effect sizes were associated with interventions that specifically focused on depression, participant selection based on depression history or symptoms (with or without other risk criteria being considered), and more recent year of publication. Smaller trials were more likely to have depression-focused interventions and to have selected participants based on depression symptoms or history. Therefore, we suspect that these other characteristics may be in part responsible for the small studies effect.

Figure 7 Funnel Plot for Dichotomous Depression Outcome (Any Incidence, Prevalence, and Exceeding Symptom Scale Cut-Off)

Abbreviations: RR = Risk ratio; SE = Standard error

This figure is a funnel plot for dichotomous depression outcomes (any incidence, prevalence, and exceeding symptom scale cut-off).

We found no association between effect size and the following study characteristics: whether the study was conducted in the United States, study quality, percent followup, time to followup, number of weeks between end of the intervention and followup assessment, recruitment through self-selection requiring potential participants to contact researchers if they wanted to join (e.g., through media ads, flyers, posters), type of intervention (counseling, health system, education, support, etc.), duration of intervention, planned number of intervention sessions, estimated planned contact minutes with interventionists, parenting/attachment focus, CBT approach, IPT approach, whether group sessions were offered, whether individual sessions were offered, type of control group, whether the majority of patients were Hispanic and nonwhite participants (among trials conducted in the United States), whether adolescents were included in sample, and whether low-SES women were targeted. We did not have enough between-study variability to effectively explore the impact of targeting adolescents, having the intervention delivered in person (vs. other avenues), involvement of the primary care team, and exclusion of women with a depression diagnosis at baseline.

There was no evidence that results were exaggerated due to the inclusion of symptom cutoff scores with incidence and prevalence (see “Reported Outcome” section of Figure 2 and Table 4). Pooled effects were similar when all types of dichotomous depression status outcomes were combined and when only incidence was pooled and when only incidence and prevalence were pooled. This finding held up when we excluded from the analysis omega-3 fatty acids and debriefing interventions (which were not beneficial).

#### Other Outcomes

Other health outcomes (e.g., other mental health-related outcomes, functioning, quality of life, infant/child outcomes) were sparsely reported and were less likely to show beneficial effects than depression outcomes. They are discussed in more detail in the sections describing results for each intervention type.

### Results by Intervention Type

#### Counseling Interventions

##### Study and Intervention Characteristics

We identified 20 trials (2 good-quality, 18 fair-quality) of counseling interventions (n=4107). Over half were conducted in the United States (12/20 [60%], most were limited to adults (17/20 [85%]), and most initiated the interventions during pregnancy (17/20 [85%]). Three-quarters of the trials were limited to women who were known to be at increased risk of PND, due to depression history or symptoms (6/20 [30%]), nondepression-related risk factors (3/20 [15%]), or either depression-related or other risk factors (6/20 [30%]). Almost two-thirds (13/20 [65%]) of the trials excluded women who met diagnostic criteria for current major depression or scored above a prespecified cutoff on a symptom severity scale. Generally, the trials that did not exclude women with a depression diagnosis or high symptom level used either unselected populations or selected participants based on nondepression-related criteria, so the proportion with depression was estimated or reported to be well below 50 percent. Eight of the counseling studies included primarily nonwhite participants.

Counseling interventions lasted a median of 8 weeks (IQR 5 to 20 weeks), included a median of eight sessions (IQR 5 to 11 sessions), and had an estimated median of 12 hours of contact (IQR 4 to 23.3 hours). Most of the interventions used CBT or IPT approaches. One CBT approach, used in four studies,^38,^ ^79,^ ^83,^ ^84^ was the “Mothers and Babies” program, which had both English- and Spanish-language versions. The program involved 6 to 12 weekly 1- to 2-hour group sessions during pregnancy and 2 to 5 postpartum booster sessions. It was designed for women who did not meet criteria for depression, was described as a “course” rather than group “therapy,” and had a stated goal of helping participants create a healthy physical, social, and psychological environment for themselves and their infants. Two of the trials implemented this intervention in the context of a home-visiting program for low-income women; intervention participants were provided transportation to the group sessions, and both intervention and control participants received the home-visiting service.^38,^ ^79^ The “Mothers and Babies” program included modules on cognitive-behavioral theory of mood and health, physiological effects of stress, importance of pleasant and rewarding activities, cognitive distortions and automatic thoughts, social networks, positive mother-child attachment, and parenting strategies to promote child development and secure attachment in infants.

Another commonly used approach, studied in five trials, was the IPT-based ROSE program.^41,^ ^42,^ ^86-88^ This program involved four or five 60- to 90-minute prenatal group sessions and one individual 50-minute postpartum session. Course content included psychoeducation on “baby blues” and postpartum depression; provision of a rationale for the interpersonal focus of the program; stress management; development of a social support system; identification of role transitions and changes associated with role transitions; discussion of types of interpersonal conflicts common around childbirth, techniques for resolving them, and role-playing exercises with feedback from other group members.

Across all interventions, it appeared that generally between half to three-quarters of all possible sessions were attended, across all participants, although adherence information was not always available, and reporting was quite variable. Some studies reported low attendance, such as one United Kingdom-based CBT trial^53^ reporting that only 46 percent of participants attended three or more of the eight sessions available, but several other studies reported adherence on the order of 80 percent or more of sessions attended on average across participants.^38,^ ^79,^ ^81,^ ^90^

##### Depression Outcomes

Counseling interventions were associated with a 39 percent reduction in the likelihood of PND when the outcomes of incidence, prevalence, and exceeding symptom cutoffs were combined (pooled RR=0.61 [95% CI, 0.47 to 0.78], k=17, n=3094, I^2^=39%, Figure 3) (see also Appendix E Figure 1 showing population selection and whether the intervention focused on depression). The proportion of participants with depression according to any of the dichotomous depression outcomes at the main timepoint of 26 weeks postpartum (or the closest to this timepoint) ranged from 0 to 34% in the intervention groups, compared with 6 to 50% in the control groups, with absolute reductions in risk ranging from 1.3% greater reduction in the control group to 31.8% greater reduction in the intervention group. Of these trials, 13/17 (76%) reported an outcome of major depressive disorder diagnosis based on a clinical interview. Seventeen of the of 20 included counseling studies reported this outcome; the three that did not^72,^ ^91,^ ^92^ all reported continuous measures of depressive symptoms, with one^91^ reporting a statistically significant difference between groups (mean difference in change between group was −0.7 points on 4-point scale) and another reported a 1.6-point difference on the EPDS at followup among the participants who scored 7 or lower on the EPDS at baseline (95% CI, 0.17 to 3.15, p=0.05), but did not find group differences overall.^72^ Trials reported outcomes over a wide range of followup timepoints, ranging from 6 to 52 weeks postpartum.

Most of the counseling trials were limited to women at increased risk for PND, and analysis of the subgroup of trials targeting women at increased risk showed a clear beneficial effect with a 45% reduction in the likelihood of depression (pooled RR=0.55 [95% CI, 0.44 to 0.68], k=14, n=1411, I^2^=0%, data not shown). The pooled effect was not statistically significant among three trials with population that were not selected for increased risk (pooled RR=0.79 [95% CI, 0.48 to 1.30], k=3, n=1683, I^2^=66%, data not shown). Since most trials examined interventions that specifically targeted depression, we could not assess the impact of this factor in the counseling intervention trials. There was no clear pattern of larger or smaller effects at earlier or later followup. We also detected no association between effect size and the specific outcome reported (incidence, prevalence, exceeding a symptom cutoff), or amount of contact time. Attendance may have been associated with effect size. Of the five trials with the smallest effects (RR>0.80), three did not report session attendance^93-95^ and two had lower-than-typical attendance: one reported that women attended only about half of the sessions on average^84^ and the other reported approximately 60 percent attendance in a high-risk group of women who had recently experienced intimate partner violence.^88^

The 13 trials that reported continuous symptom score measures showed a wide range of results, and group differences were statistically significant in five trials.^38,^ ^79,^ ^86,^ ^89,^ ^90^ Counseling interventions were associated with a small beneficial effect, amounting to a pooled standardized effect size of 0.2, which would generally be considered a small effect,^96^ or a 1.5-point greater reduction in depression symptom severity than control conditions when analyzed in the questionnaires’ original metrics (standardized mean difference [SMD]= −0.21 [95% CI, −0.40 to −0.02 [data not shown], weighted mean difference in change between groups [WMD]= −1.51 [95% CI, −2.84 to −0.18], k=13, n=1367, I^2^=61%, Figure 6). This analysis combined a variety of instruments with 30- to 63-point ranges.

Examination of the subgroups of studies reporting the use of CBT approaches or IPT approaches separately showed that the effects were similar for these subsets of trials to the overall effect of counseling interventions (Figure 2, under “Counseling Approach”). Further, both the “Mothers and Babies” program and ROSE program subgroups of trials showed pooled reductions of 50 percent or more in the risk of PND, although confidence intervals overlapped with the overall effect of counseling interventions (“Mothers and Babies” RR=0.47 [95% CI, 0.26 to 0.84], k=4, n=325, I^2^=0%; ROSE program RR=0.50 [95% CI, 0.32 to 0.80], k=5, n=464, I^2^=12%). However, only the smallest and first published^86^ of the ROSE program and related trials reported a statistically significant (or clinically important) reduction in continuous depression symptom scores; two others reported between-group differences in change of less than 0.3 points on the EPDS^88^ and Beck Depression Inventory [BDI]^87^ at 13 weeks postpartum, and two did not report symptom scale scores.^41,^ ^42^ All four of the “Mothers and Babies” studies also reported continuous symptom scale scores; two trials^83,^ ^84^ showed no between-group differences and two showed greater reductions on the BDI by 6 or more points than the control groups.^38,^ ^79^ Some other counseling approaches also reported large and statistically significant effects comparable to the “Mothers and Babies” approach, such as a program incorporating CBT and mindfulness therapy (RR=0.36 [95% CI, 0.18 to 0.72] at 6 months postpartum),^90^ an individually-based 8-session CBT phone counseling approach (RR=0.34 [95% CI, 0.14 to 0.78] at 12 weeks postpartum),^97^ and an 8-session couples’ co-parenting class, which focused on affirming the other parent’s competence, acknowledging and respecting the other parent’s contributions, and upholding their partner’s parenting decisions and authority (β=-0.20 [SE 0.06], p<0.01 at 6 months postpartum).^91^

##### Other Outcomes

Most of the counseling trials also reported other maternal or child outcomes; however, there was a wide variety of outcome measures and little consistency across studies. Stress and anxiety were the most commonly reported outcomes, shown in Figure 8, for trials that reported sufficient data to plot. Four trials^89,^ ^92,^ ^97,^ ^98^ reported a measure of stress, such as the stress subscale of the Depression, Anxiety, and Stress Scale (DASS), the Perceived Stress Scale, or the number of stressful events over a specified time period. Most did not show statistically or clinically important differences between groups, but one^97^ trial showed a benefit, reporting a 5.7-point greater reduction (95% CI, −9.8 to −1.6) in intervention group participants than control group participants at 12 weeks postpartum on the 21-point stress subscale of the DASS. This trial examined an eight-session CBT phone intervention spanning both pregnancy and the early postpartum period, was conducted in Australia, and also showed improvements in depression outcomes. Four trials^81,^ ^91,^ ^92,^ ^97^ reported an anxiety measure, such as the anxiety subscale of the DASS, the Taylor Manifest Anxiety Scale, and the Anxiety subscale of the Symptom Checklist 90 (SCL-90). The same Australian trial finding a reduction in stress also found a 4.3-point greater reduction (95% CI, −6.6 to −2.0) in intervention than in control group women on the DAS anxiety subscale, but other trials found no such differences. Other outcomes, generally reported by only one or two studies, included measures of functioning (general,^53,^ ^87^ maternal,^81^ and family^81,^ ^89,^ ^94^), quality of life,^94^ social support,^38,^ ^89^ trauma symptoms,^88^ mental health treatment,^42^ breastfeeding,^87^ child development,^95^ child attachment,^95^ birth weight^89^, and preterm birth.^89^ Of these, one trial showed statistically significant benefits on birthweight (between-group difference=283g, p=0.01) and incidence of preterm birth (RR=0.19 [95% CI, 0.06 to 0.65], 3/69 [4.4%] in the intervention group, 13/58 [22.4%] in the control group) in a European study of using psychosomatic humanist model of treatment.{Ortiz Collado, 2014 #264} Several other outcomes did trend in the direction of benefit, but many did not. Detailed results for all outcomes are shown in Appendix F Tables 5–7.

Figure 8 Forest Plot of Anxiety and Stress Scale Scores for Counseling Intervention Trials

Note: For followup time, “g” indicates during gestation and “p” indicates postpartum; thus, for example, g37=37 weeks’ gestation and p12=12 weeks postpartum

Abbreviations: CG = Confidence interval; CI = Confidence interval; DASS = Depression, Anxiety, Stress Scale; G = gestational period (weeks); IG = Intervention group; P = postpartum period (weeks); PSS = Perceived Stress Scale; SCL = Symptom Checklist; SD = Standard deviation; STAI = State-Trait Anxiety Inventory; WMD = Weighted mean difference

This figure is a forest plot of anxiety and stress scale scores for counseling intervention trials.

#### Health System Interventions

##### Study and Intervention Characteristics

Three^66,^ ^73,^ ^74^ fair-quality trials (n=5321 randomized) examined the effects of health system-level interventions. None limited their sample to women at increased risk of depression. One trial, however, reported results separately for women who screened positive and negative at the 6-week postpartum visit, early in the intervention process, so we abstracted only the data on women who screened negative (EPDS<12), since this was the PND prevention cohort.^66^

One study (n=433) was conducted in The Netherlands and trained midwives in screening and management of maternal distress during pregnancy.^74^ Women were enrolled at 4 to 14 weeks gestation. The intervention included training midwives in specially developed clinical pathways, giving them maps of local caregivers available for referral, and providing formats for client meetings, consultations, and referrals. This intervention also included a web-based tool offered to pregnant women in the intervention practices that assessed their personal circumstances, stressors, and mood. Additionally, a printout was provided with personalized feedback based on the web-based assessment tool, covering areas such as advice for everyday life, positive ways of coping, resources for self-management, and information about local lay workers, support groups, and local health care providers for psychological help and support.

The other two trials were conducted in the United Kingdom. One (n=2064) focused on training midwives how to use specially developed guidelines on screening and management of depression and other mental health issues during postpartum care, along with providing enhanced, ongoing support for managing their clients’ mental health needs.^73^ This trial also extended home visiting services to 10 to 12 weeks, compared with the typical 2- to 4-week window routinely offered to postpartum women in the United Kingdom. Home visitors are specialist community nurses who support infant care and establish a supportive relationship with the mothers but have only basic mental health training. The other trial conducted in the United Kingdom (n=2824) involved training home visitors in postpartum mental health assessment and in developing a warm, therapeutic relationship with their clients. In addition, health visitors were trained in two different manualized counseling programs for depression, one that used a CBT approach and one of nondirective person-centered counseling.^66^ Women who scored 12 or higher on the EPDS at 6 or 8 weeks postpartum were offered up to 8 weekly counseling sessions of either CBT or person-centered counseling. The results reported here are for women who screened negative at 6 weeks postpartum, so only the few women who converted to a positive EPDS between weeks 6 and 8 were offered counseling in this subgroup. Thus, results reported here are primarily for the enhanced assessment and relationship-building by the health visitors, and only among those who had not developed a high level of depressive symptoms by 6 weeks postpartum.

##### Depression Outcomes

All three programs showed beneficial effects, with a pooled 40 percent reduction in the likelihood of scoring above an EPDS cutoff (RR=0.60 [95% CI, 0.43 to 0.83], k=3, n=4738, I^2^=66%, Figure 3, Appendix E Figure 1). However, a REML analysis, which better accounts for the small number of trials being pooled, did not find the pooled effect statistically significant (RR=0.58, 95% CI, 0.22 to 1.53, I^2^=66%). However, the RRs were 0.71 or lower and statistically significant in all three trials. The trial in The Netherlands addressing care of pregnant women^74^ reported that 6.4 percent of women in the intervention group scored 10 or higher on the EPDS at approximately 37 weeks gestation, compared with 19.5 percent of women in the control group (RR=0.33 [95% CI, 0.19 to .0.55]). In the United Kingdom trial that provided enhanced training for midwives’ care of postpartum women, 14.4 percent of the intervention group women scored 13 or higher on the EPDS at approximately 17 weeks postpartum, compared with 21.3 percent of the control group (study-reported OR=0.47 (95% CI, 0.31 to 0.76).^73^ The smallest effect was seen in the trial limited to women who did not meet their threshold for depression treatment at 6 weeks postpartum (RR=0.71 (95% CI, 0.53 to 0.95, ARD=-3.1%) All three trials also found statistically significant differences in continuous EPDS scores, ranging from a 3.3-point greater reduction in the intervention than the control group (95% CI −4.0 to −2.6)^74^ to a mean difference in EPDS between groups of −0.5 (95% CI, −0.9 to −0.1) at 13 weeks postpartum.^66^

##### Other Outcomes

Both of the United Kingdom trials^66,^ ^73^ in postpartum women reported Short form (SF)-36 physical and mental component scores, but there were differences for only one trial,^73^ and only for the mental components score; the intervention group scored 4.3 points higher (95% CI, 2.5 to 6.1) than the control group at 17 weeks postpartum. In addition, the Dutch trial in pregnant women also reported approximately 4.5-point greater reductions on two different anxiety instruments in the intervention over the control group.

#### Physical Activity Interventions

##### Study and Intervention Characteristics

We identified three trials (n=1200) of physical activity programs that had a specific aim of preventing PND, all in general risk (unselected) populations. The largest study (n=855) was conducted in Norway^99^ and involved 12, 60-minute group exercise sessions for pregnant women with instructions for home exercise and dietary advice. Another study was conducted among pregnant women in Spain who began their intervention at 9 to 12 weeks’ gestation; it involved three 60-minute group exercise sessions per week for 30 weeks and was the only one rated as good-quality.^100^ The final study (n=184), conducted in Australia,^101^ consisted of eight 60-minute group exercise classes plus 30-minute health education sessions (n=161). None of the trials reported adherence (e.g., number of sessions attended).

##### Depression Outcomes

Physical activity intervention resulted in a 46 percent reduction in the risk of scoring above a cutoff on the EPDS or CES-D (pooled RR=0.54 [95% CI, 0.33 to 0.87], k=3, n=1021, I^2^=0%, Figure 3, Appendix E Figure 1). However, a REML analysis, which better accounts for the small number of trials being pooled, did not find the pooled effect statistically significant analysis (RR=0.54 [95% CI, 0.18 to 1.57], I^2^=0%). The good-quality trial from Spain was the only one that reported a statistically significant effect, finding that 12.2 percent of those in the exercise intervention scores 16 or higher on the CES-D at approximately 39 weeks’ gestation, compared with 24.7 percent in the control group (RR=0.48 [95% CI, 0.25 to 0.97]). Two of these trials also reported 3- to 4-point greater reductions in depressive symptom scores in intervention participants than those in control groups (pooled WMD=-3.45 [95% CI, −5.0 to −1.9), k=2, n=302, I^2^=0%, Figure 6).

##### Other Outcomes

The Australian trial in postpartum women reported 1.3-point (95% CI, 0.6 to 2.0) and 1.4-point (95% CI, 0.7 to 2.1) greater increases on a positive coping scale at 16 and 20 weeks postpartum, respectively. The other trials did not report other relevant outcomes.

#### Educational interventions

##### Study and Intervention Characteristics

Six trials (n=2949) tested the effects of an educational intervention without counseling or extensive supportive elements,^75,^ ^76,^ ^80,^ ^102-104^ using a variety of approaches. Generally, these trials targeted unselected populations. The only trial that targeted women at increased risk for PND involved a single mailing of PND information to first-time mothers in Hong Kong who had scored 10 or higher on the EPDS at 4 to 6 weeks postpartum (N=70).^102^ Four of the trials were rated as fair-quality; the other two were good-quality trials that explored the effects of general postpartum (n=400)^80^ and prenatal (n=1193)^104^ courses. The prenatal course included a module addressing postpartum depression in addition to typical content on labor and delivery, infant care, and the couples’ transition to parenthood. Session attendance in this trial ranged from 72 to 85 percent of participants across the three sessions. The postpartum course, for couples up to 6 weeks postpartum, posited that day-to-day interactions among a new mother, her partner, and the infant can increase or decrease the risk of mental health issues, and targeted emotional and interpersonal functioning more generally. This intervention was delivered in a single 6-hour session. Two of the trials involved a brief session in the hospital postdelivery and a brief followup phone call 2 weeks later; these were the only educational intervention trials conducted in the United States (n=540 in each study).^75,^ ^76^ In these, the intervention was successfully delivered to 97 percent of the participants. The final trial (n=206) involved a single PND education session with a midwife at 12 to 28 weeks’ gestation.^103^

##### Depression Outcomes

The only educational intervention that reported a statistically significant benefit at the main followup timepoint (the closest to 6 months postpartum) was the trial in Hong Kong, which found that 40 percent of the intervention group women scored 10 or higher on the CES-D at 13 weeks postpartum, compared with 68.6 percent in the control group (Figure 4, Appendix E Figure 2).^102^ One of the U.S.-based trials of two brief postpartum educational sessions found benefits of treatment at 3 weeks postpartum, but the effect attenuated and was no longer statistically significant at 13 weeks and beyond.^75^ However, among women who did not exhibit depressive symptoms at baseline in this study, the effect was maintained through 13 weeks, when 6.3 percent of the intervention women and 11.4 percent of the control women had scored 10 or higher on the EPDS (adjusted OR=0.45 [95% CI, 0.21 to 0.92]).^75^ The trial in Hong Kong also reported a 1.5-point greater reduction on the EPDS among those in the intervention group, but there was no difference in symptom scores in the good-quality trial of the prenatal education course.^80^

##### Other Outcomes

Only one^80^ trial reported other relevant outcomes. It found no group differences on measures of anxiety, fatigue, mother-infant attachment, breastfeeding, and unsettled infant behavior.

#### Supportive Interventions

##### Study and Intervention Characteristics

Seven trials (n=4569) tested the effects of some type of supportive intervention (but without formal counseling) ^67,^ ^68,^ ^77,^ ^82,^ ^105-107^ using a variety of approaches and a variety of population selection criteria. None of these trials were conducted in the United States. Two trials, both set in the United Kingdom, were rated as good-quality.^67,^ ^68^ One of them (n=1324) involved support by a lay case manager for women with social risk factors;^68^ the other (n=731) had two intervention arms: one of an enhanced referral process to community support organizations and one that enlisted a home visitor to provide up to 22 supportive listening visits.^67^ Another U.K.-based trial (n=623) also involved a support worker visiting new mothers in their homes, in this case 10 3-hour visits in the first 4 weeks postpartum to provide practical and emotional support.^82^ Two trials in Canada had women who had previously experienced PND provide telephone-based peer support to women who had scored 10 or higher on the EPDS at 2 weeks (n=701)^77^ or 8 to 12 weeks (n=42)^105^ postpartum. The mean number of calls completed were 5.4^105^ and 8.8.^77^ The final two trials examined the effects of nondirective support groups, one for unselected pregnant British women (N=1004)^106^ and one for Australian women scored as having increased risk of PND on a prenatal screening questionnaire (N=144).^107^ However only 18 percent of the women in the British trial^106^ attended any group sessions, and the overall attendance rate was 31 percent of all sessions in the Australian trial.^107^

##### Depression Outcomes

Three of the trials showed benefits of treatment, although effects were not large,^77^ of marginal statistical significance,^68^ or based on a very small sample (Figure 4, Appendix E Figure 2).^105^ The good-quality trial of supportive lay case managers found that 12 percent of the intervention women scored 13 or higher on the EPDS at 8 weeks postpartum, compared with 17 percent in the control group (unadjusted RR=0.74 [95% CI, 0.55 to 1.01, adjusted p=0.05).^68^ In addition, both trials of peer phone support found improved outcomes in intervention women. The first, smaller trial found that 15 percent of the women in the intervention group scored 13 or higher on the EPDS at 18 weeks postpartum, compared with 52 percent in the control group (n analyzed=42).^105^ The second trial did not report depression status but found a small statistically significant effect on depression symptom severity at 12 weeks postpartum: intervention group women scored 1 point lower on the EPDS than control group women (t-test p-value=0.02); however, the effect disappeared at 24 weeks postpartum.^77^

##### Other Outcomes

The U.K.-based good-quality trial with two intervention arms (up to 22 in-person supportive listening home visits and referral to community support services) reported a large number of other outcomes, but found no beneficial impact of either intervention arm on any outcomes relevant to this review, including measures of social support, acute health care utilization (both mothers and infants), antidepressant use, other medication use, and breastfeeding.^67^ Other trials similarly found no impact on acute health-care utilization,^108^ birth outcomes (birthweight, preterm birth, admission to neonatal intensive care unit (NICU), postpartum hemorrhage, perinatal mortality),^68^ social support,^77,^ ^106,^ ^108^ and anxiety.^77^ One trial did report increased rates of exclusive breastfeeding at 6 weeks postpartum,^68^ but another trial did not find an impact on breastfeeding.^82^

#### Other Behavior-Based Interventions

##### Study and Intervention Characteristics

Seven fair-quality trials (n=3932) tested the effects of other behavior-based interventions, using a wide variety of approaches and a variety of population selection criteria.^44,^ ^78,^ ^85,^ ^109-112^ Three trials targeted infant sleep: in unselected early postpartum women (n=770),^78^ mothers of 6- to 12-month-old infants who reported infant sleep problems (n=156),^109^ and pregnant women with elevated scores on a postpartum depression prediction index (n=54).^85^ Two trials explored the effectiveness of a childbirth-experience debriefing program in the immediate postpartum period (1–3 days postpartum) in unselected women (n=1745)^111^ and women who had an operative delivery (n=1041).^44^ One trial assessed the benefits of eight 75-minute yoga classes (n=46)^110^ in pregnant women scoring 10 or higher on the EPDS, and another examined the value of an expressive writing intervention in unselected women on day 3 postpartum (n=120).^112^ The expressive writing task was to undertake two sessions of writing about the deep emotion connected with delivery and childbirth, versus describing daily events in behavioral terms in the control condition. The trial of yoga^110^ and one of the sleep intervention trials^85^ were conducted in the United States.

##### Depression Outcomes

Of the infant sleep studies, the large trial in unselected early postpartum women found a 39 percent reduction in the likelihood of scoring 10 or higher on the EPDS at 6-month followup (study-reported adjusted OR=0.57 [95% CI, 0.34 to 0.94]),^78^ and the other two reported statistically significant or near-significant reductions in symptom severity scores at one (but not all) timepoints on one (but not all) depression instruments. No benefits were seen for yoga (difference in change in depression symptoms at post-test: 0.1 [95% CI, −.3.2 to 3.5]), debriefing (pooled RR=1.04 [95% CI, 0.88 to 1.22], k=2, n=2662 I^2^=27%), and expressive writing (RR=0.55 [95% CI, 0.20 to 1.53]). Debriefing was the only one of these examined in more than one study and was studied in over 2000 women. Results did not trend in the direction of benefit for either study.

##### Other Outcomes

The infant sleep trial initiated during pregnancy in women with elevated PND risk reported reduced anxiety scores at 6 and 16 weeks postpartum;^85^ the other two infant sleep trials did not report other relevant outcomes. Yoga did not improve anxiety,^110^ and debriefing interventions did not lead to improvements in functioning^44^ or reduce the likelihood of a post-traumatic stress disorder (PTSD) diagnosis.^111^ The trial of expressive writing, however, reported a 2.1-point greater reduction (95% CI, −2.9, −1.3) on a PTSD symptom scale in intervention- than control-group women, and a reduced likelihood of scoring above 6 on the Perinatal PTSD Questionnaire (RR=0.35 [95% CI, 0.15 to 0.81]).

#### Pharmacotherapy and Dietary Supplements

##### Study and Intervention Characteristics

We identified four trials of chemoprevention of PND (n=307) that assessed the effects of nortriptyline (n=58),^46^ sertraline (n=22),^45^ and omega-3 fatty acids (n=227).^50,^ ^51^ All four trials were conducted in the United States. In the antidepressant trials (both fair-quality), women with a history of postpartum depression in the previous 5 years were randomized to receive either an antidepressant (75 milligrams [mg]/day of nortriptyline^46^ or 50 mg/day of sertraline^45^) or placebo for 17 weeks, starting as soon as possible after birth, followed by a 3-week tapering phase. One of the omega-3 fatty acids trials (n=126), the only good-quality chemoprevention trial, randomized pregnant women who had either elevated EPDS scores or a history of depression to daily ingestion of either eicosapentaenoic acid (EPA)-rich fish oil supplementation (1060 mg EPA plus 274 mg DHA), DHA-rich fish oil supplementation (900 mg DHA plus 180 mg EPA), or soy oil placebo, beginning between 12 and 20 weeks gestation for a total of 32 weeks duration.^50^ The other omega-3 fatty acids trial randomized unselected participants to receive either an algae-derived triglyceride capsule that provided approximately 200 mg of DHA per day (n=51) or a placebo capsule (n=50) beginning within 1 week of delivery.^51^

##### Depression Outcomes

In the trials of antidepressants, nortriptyline offered no preventive benefits compared with placebo (Figure 5, Appendix E Figure 3).^46^ Neither the rates of recurrence between those taking nortriptyline and those taking placebo (23% vs. 24%, p=1.00) nor the time to postpartum recurrence (p=0.83) differed between the two groups. Of note, 5 of the 26 patients assigned to nortriptyline were considered nonadherent, as their nortriptyline levels were <50 ng/ml. No other depression outcomes were reported. The trial of sertraline found that a smaller percentage of those taking sertraline had a depression recurrence compared with those taking placebo (7% vs. 50%, p=0.04) at 20 weeks postpartum.^45^ Further, the time to recurrence was faster in those receiving placebo (p=0.02). No other depression outcomes were reported.

In both omega-3 fatty acids trials, there were no between-group differences on any depression outcomes at any timepoint, nor did they trend in the direction of benefit.^50,^ ^51^ Similarly, there was no difference between the proportion of women who were started on antidepressants (ranging from 10% [placebo] to 18% [DHA]) or in the antidepressant dose requirements in the trial in women with elevated depressive symptoms or a history of depression.^50^

##### Other Outcomes

Neither trial of antidepressants reported other maternal health outcomes or child outcomes. In the omega-3 fatty acids trials, other maternal health outcomes differed minimally. Supplementation with omega-3 fatty acids led to a small but statistically significantly lengthened gestational period (40.4 [DHA] vs. 39.1[both EPA and placebo], p<0.001) but did not differ in any other measured maternal outcomes, including development of gestational diabetes or gestational hypertension/preeclampsia, induced labor, estimated blood loss, Cesarean section, or spontaneous vaginal delivery.^50^ Newborn outcomes showed a limited number of benefits for omega-3 fatty acids. Those receiving DHA supplementation had higher mean birthweight (3774 grams [DHA] vs. 3402 grams [EPA] vs. 3309 grams [placebo], p<0.001) and higher 5-minute APGAR (9.1 [DHA] vs. 8.6 [EPA] vs. 8.9 [placebo], p<0.01).^50^ Other newborn outcomes, including 1-minute Apgar score, cord arterial pH, and newborn intensive care unit admission, did not differ between groups.^50^

## Key Question 2 What Harms Are Associated With Interventions to Prevent Perinatal Depression in Pregnant or Postpartum Women?

None of the behavior-based trials reported any global harms outcomes, such as the number of individuals reporting an adverse event, for either mothers or infants. Across all behavior-based trials, none of the outcomes reported showed any pattern of increased risk of harms, based on group means. Although there were some isolated instances of control groups showing greater gains, this was rarely the case, none of these findings were statistically significant, and they appeared to fit within the bounds for variability in results that would be expected based on random variation.

Both antidepressant trials systematically collected adverse event information, using the Asberg Side Effects Scale. In the nortriptyline study,^46^ the authors stated that participants tolerated nortriptyline well, reporting no differences in withdrawals due to adverse effects, with only one person withdrawing from each arm. They reported only the number of events for 1 of the 11 side effects collected; constipation differed between groups (78% of the women taking nortriptyline vs. 22% taking placebo). For the sertraline study^45^ participants receiving sertraline were more likely than those on placebo to report dizziness (57% vs. 13%, p=0.05) and drowsiness (100% vs. 50%, p=0.02), but did not differ in rates of other adverse events (but data were not shown). Three women stopped taking sertraline due to adverse effects (21%), compared with none in the control group; however, this difference was not statistically significant. One participant each taking nortriptyline and sertraline converted to mania or hypomania, while no women taking a placebo did so; this difference was not statistically significant for either agent, although the studies were not powered for this outcome. We found no additional studies (trials or observational studies) that addressed harms of sertraline in postpartum women.

No harms were associated with omega-3 fatty acids,^50^ although reports of adverse events were collected spontaneously rather than systematically through a validated instrument, and adherence was by self-report. The study noted no significant differences in the proportion of participants reporting gastrointestinal side effects or adherence with the recommended intervention.