# Chapter 2 Methods

## Scope and Purpose

This report will be used by the USPSTF to support a new recommendation on “Interventions to Prevent Perinatal Depression.”

## Key Questions and Analytic Framework

In consultation with members of the USPSTF, we developed an analytic framework (Appendix A Figure 1) and two Key Questions (KQs) to guide our review.

1. Do interventions to prevent perinatal depression improve health outcomes in pregnant or postpartum women or their children?
  a. In trials that limit enrollment to high-risk women, how are participants identified as being at high risk of developing perinatal depression?
2. What harms are associated with interventions to prevent perinatal depression in pregnant or postpartum women?

## Data Sources and Searches

We identified two existing systematic reviews with fair to good search strategies and inclusion criteria that were at least as inclusive as ours.^59,^ ^60^ We evaluated all articles included in either of these reviews for inclusion in the current review. We developed a search strategy designed to capture studies of interventions to prevent PND published 12 months prior to the end of the search window for these reviews (Appendix A). We then searched the following databases for relevant English-language literature published between January 1, 2012, and February 6, 2018: MEDLINE, PubMED (for publisher-supplied records only), PsycINFO, and the Cochrane Central Register of Controlled Trials. A research librarian developed and executed the search, which was peer-reviewed by a second research librarian.

In addition, we examined the reference lists of other previously published reviews, meta-analyses, and primary studies to identify additional potential studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts. We also searched ClinicalTrials.gov (https://ClinicalTrials.gov/) for ongoing trials. We imported the literature from these sources directly into EndNote® X7 (Thomson Reuters, New York, NY).

## Study Selection

We developed specific inclusion criteria to guide our study selection (Appendix A Table 1). For the key question addressing benefits of interventions (KQ1), we included English-language randomized controlled trials (RCTs, including cluster randomized trials) and nonrandomized controlled trials that included a usual care, no intervention, minimal control, attention control comparison group, or placebo for medication trials, and followed participants for at least 6 weeks. For KQ2 (harms of interventions) we included RCTs, nonrandomized controlled clinical trials, systematic reviews, and large comparative cohort studies for harms of antidepressant use only; there was no minimum followup requirement for studies of harms. For harms of antidepressants, we only included harms of agents with evidence on efficacy (i.e., agents addressed in KQ1 trials). We excluded prospective and retrospective cohort studies, case control studies, time series studies, before-after studies with no comparison group, cross-sectional studies, case studies, case series, and editorials/commentaries.

For both key questions, we included studies conducted among pregnant individuals and mothers up to a maximum of 1 year postpartum. Studies may have targeted those with mental health symptoms or disorders; however, we excluded studies limited to perinatal persons currently experiencing or being treated for a depressive episode (since the focus of this review is on prevention of depression) and studies limited to those with psychotic or developmental disorders (e.g., schizophrenia, pervasive development disorder). In addition, we excluded studies limited to persons with a medical condition (e.g., HIV/AIDS), those limited to spouses or domestic partners, and those limited to persons in institutions (e.g., psychiatric inpatients, prison inmates) or long-term care or residential facilities. We included studies that contained mixed populations that may have included a subset of these types of participants; however, we required that the number not exceed 50 percent of the total population to be considered for inclusion.

We required that studies have a primary or secondary aim to prevent PND. We included the following interventions: counseling (e.g., CBT, interpersonal therapy [IPT], nondirective counseling, debriefing), psychoeducation, or other supportive interventions (e.g., peer mentoring, support group); care delivery models targeting improved mental health outcomes; prophylactic use of antidepressants (i.e., tricyclic antidepressants and monoamine oxidase inhibitors, selective serotonin reuptake inhibitors, selective norepinephrine reuptake inhibitors, dopamine reuptake inhibitors, 5-HT_2A_ receptor antagonists, serotonin reuptake inhibitors, tetracyclic antidepressants); widely available physical activity or complementary and alternative therapies (i.e., massage, acupuncture, hypnosis, light exposure, yoga); and hormonal therapy (e.g., estrogen, oxytocin, thyroxine). For pharmacotherapy harms, we planned to examine only harms of medications with any evidence to support their use for prevention of PND, and only during the phase (pregnancy or postpartum) in which the evidence lay. Sertraline use during the postpartum period was the only medication we identified with evidence of possible benefit. In addition, we excluded interventions comprised of general parenting education without a mental health component (e.g., prenatal or infant care classes).

Depression diagnosis or symptoms were a required outcome for included studies. Depression diagnosis is determined through a clinical interview, typically using standardized instruments such as the Composite International Diagnostic Interview.^61^ Depressive symptoms are measured using a wide variety of instruments which may be developed for general adult populations (e.g., the Center for Epidemiological Studies Depression Scale [CES-D]^62^) or specifically for use in perinatal women (e.g., the Edinburgh Postnatal Depression Scale [EPDS]^63^) We also abstracted other maternal health outcomes (e.g., suicide-related variables, health-related quality of life, breastfeeding, functioning), infant/child outcomes (e.g., neglect or abuse; physical, social, emotional, and behavioral development; attachment), birth outcomes (preterm birth, low birth weight, preeclampsia), and harms (e.g., number of adverse events).. See Appendix A Table 1 for a detailed list of outcomes that were abstracted. We included relevant outcomes reported at least 6 weeks after the baseline assessment or intervention initiation, although for harms we considered outcomes reported any time after the intervention was initiated.

We included interventions that were conducted in or recruited from primary care or a health care system or that could be implemented in or referred from primary care. This included intervention taking place in primary care clinics; prenatal clinics; obstetrics/gynecology clinics; pediatrics; family planning clinics; military health clinics; school-based health clinics; mental health clinics; and research clinics/offices, homes, or other community settings, including electronic or computer-based interventions. We excluded studies conducted in correctional facilities, school classrooms, worksites, and emergency departments. Trials had to be conducted in countries ranked as having “very high” human development according to the World Health Organization.^64^

Two reviewers independently reviewed titles and abstracts for potential inclusion, then two reviewers reviewed the full-text articles. Discrepancies were resolved via discussion and third-party consultation as needed. Title, abstract, and full-text review were conducted in DistillerSR (Evidence Partners, Ottawa, Canada).

## Quality Assessment and Data Abstraction

Two reviewers applied USPSTF design-specific criteria (Appendix A Table 2)^65^ to assess the methodological quality of all eligible studies. We assigned each study a quality rating of “good,” “fair,” or “poor.” Discordant quality ratings were resolved by discussion or by a third reviewer and adjudicated as needed. Studies rated as “poor” quality were excluded from the review.

Good-quality studies were those that met all or nearly all of the specified quality criteria (e.g., comparable groups were assembled initially and maintained throughout the study, followup was 90% or higher, assessment procedures were described and blinded if they involved direct interview, randomization methods were described, allocation was concealed), whereas fair-quality studies did not meet all these criteria but did not have serious threats to their internal validity related to the design, execution, or reporting of the study. Intervention studies rated as poor quality generally had several important limitations, including at least one of the following risks of bias: very high attrition (generally >40%), differential attrition between intervention arms (generally >20%); lack of baseline comparability between groups without adjustment; or problematic issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting; inappropriate exclusion of participants from analyses; questionable validity of allocation or assessment procedures).

For all of the included studies, one reviewer extracted key elements into standardized abstraction forms in DistillerSR (Evidence Partners, Ottawa, Canada), and a second reviewer checked the data for accuracy. For each study, we abstracted general characteristics of the study (e.g., author, year, study design), clinical and demographic characteristics of the sample and setting (e.g., age, race/ethnicity, baseline clinical characteristics, setting, country), intervention characteristics, and results. For intervention characteristics of trials, we abstracted detailed information including setting, timing of the intervention (during pregnancy, postpartum period, or both), mode of delivery (i.e., in-person, telephone, electronic, or print); therapeutic or intervention approach (e.g., cognitive behavioral therapy, interpersonal therapy), duration, number, and length of sessions; providers and provider training; and adherence. We estimated the planned hours of contact based on the number and length of contacts.

## Data Synthesis and Analysis

We created summary tables showing study, population, intervention characteristics, and outcomes for qualitative evidence synthesis. Studies were examined overall and grouped according to intervention type: counseling (teaching skills designed to improve mood or function or employing therapeutic elements through contact with a counselor or facilitator), health system, physical activity, education (without counseling, extensive skills practice, or other supportive interventions), support (without counseling or skill-building), infant sleep (promoting infant sleep through such interventions as regular nap and bedtimes, teaching infants to fall asleep independently, reducing night-time feedings), debriefing (exploring the events and emotions of the birth experience, with a counselor providing normalization and education), other behavior-based approaches, antidepressants, and supplements. We used these tables along with forest plots of results to examine data for consistency, precision, and the relationship of effect size with key potential modifiers such as intervention type, population selection, followup timepoint, and publication date.

The intervention categories were developed post hoc, and some trials were difficult to categorize and could possibly have fit into more than one category. We chose the one that appeared to have the best fit. For example, one trial involved home visitors in the United Kingdom with special training in systematic assessment of depressive symptoms; establishing warm, therapeutic relationships; and in one of two counseling approaches to treat those who develop postpartum depression.^66^ This trial reported results separately for the women who had developed postpartum depression in the first six weeks postpartum (so should have received counseling from the home visitors) and those who did not. We only abstracted results for the subset who had not developed postpartum depression, therefore the intervention received by these women was really limited to the specialized training of the home visitors to have increased awareness, sensitivity to, and systematic screening of depression in their clients, which we felt was more akin to a system-level intervention than a counseling intervention. On the other hand, two other U.K.-based interventions also involved home visitors, one that trained home visitors to provide monthly “supportive listening visits” for a year^67^ and another involving case management by lay pregnancy workers that included provision of support and advice.^68^ These latter interventions seemed to emphasize the direct supportive contact rather than screening and general training, so were categorized as supportive interventions.

Due to its clinical utility, we selected depression status as our primary outcome. Most trials reported a related dichotomous depression outcome: cumulative incidence of depression (cases accumulated over a period of time, based on a diagnostic interview), prevalence (cases at a particular timepoint, based on a diagnostic interview), or the proportion scoring above a cutoff on a symptom severity scale. Since most trials excluded women with depression or high symptom levels at baseline, we assumed that most cases of depression identified after the start of the study would be new-onset cases, but not necessary first-onset, since many women had previous episodes of depression.

We ran random-effects models on both the main outcome (depression status, analyzing relative risks) and continuous measures of depression symptom severity (analyzing both standardized and unstandardized mean difference in change between groups), both overall and separately for counseling, health system, physical activity, antidepressant, and omega-3 fatty acid interventions. When studies reported more than one dichotomous outcome, we selected cumulative incidence for analysis if it was available, then prevalence if cumulative incidence was not available. When studies reported more than one continuous outcome, we preferentially selected the EPDS if it was available.

We used the DerSimonian and Laird (DL) model for pooling. In addition, because the DL method is prone to insufficient coverage of the full 95 percent confidence intervals when the number of studies is small or statistical heterogeneity is high, we also ran restricted maximum likelihood (REML) models with the Knapp-Hartung correction for small samples when pooling fewer than 10 trials and the DL model showed a statistically significant effect. For the full body of evidence, we generated a funnel plot and ran Egger’s test to explore small study effects, which can be an related to publication bias.^69^ Additionally, we conducted meta-regression and subgroup analyses to explore factors that were associated with effect size for the dichotomous depression status outcome. Meta-regressions were run for the full body of evidence (combining all intervention types) and dropping interventions with evidence of no effect (omega-3 fatty acids, debriefing). We used Stata version 15.1 (StataCorp LP, College Station, TX) for all analyses.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each key question. We adapted the Evidence-based Practice Center approach,^70^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^71^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the key questions (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there was insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body of evidence limitations field highlights important restrictions in answering the overall key question (e.g., lack of replication of interventions, nonreporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. At least two independent reviewers rated the overall strength of evidence for each intervention type. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft Research Plan for this review was available for public comment from May 19, 2016 to June 15, 2016. Comments from 33 individuals and organizations were received and resulted in updates to the proposed scope of the review. These updates included expanding the scope of the review to include prevention of depression during pregnancy and updating the terminology to be perinatal depression versus postpartum depression; the inclusion of studies with interventions that are initiated at any point during pregnancy or up to 1 year postpartum, with a minimum followup of 6 weeks or more post-baseline; and broadening the types of interventions that would be considered, as well as, the a priori subpopulations included in the review. The draft version of this report was reviewed by experts and USPSTF Federal Partners and posted for public comment on the USPSTF Web site from August 28, 2018 to September 25, 2018. Comments received during any period were reviewed, considered, and minor changes were made to the report based on these comments (e.g., clarifications, additional content, minor corrections) but no changes were made to the evidence or to our conclusions.

## USPSTF Involvement

We worked with seven USPSTF members at key points throughout this review, particularly when determining the scope and methods for this review and developing the Analytic Framework and KQs. After revisions reflecting the public comment period, the USPSTF members approved the final analytic framework, KQs, and inclusion and exclusion criteria. The Agency for Healthcare Research and Quality (AHRQ) funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.