# Chapter 1 Introduction

## Condition Definition

We define perinatal depression (PND) as the occurrence of a depressive disorder during pregnancy or following childbirth, consistent with the use of the “with peripartum onset” modifier for depressive disorders in the Diagnostic and Statistical Manual of Mental Disorders (DSM)-5 (onset during pregnancy or within 4 weeks after delivery),^1^ but expanding timeframe for postpartum onset up to one year. Depressive disorders include major depressive disorder and persistent depressive disorder (formerly called dysthymia), among others, and symptoms include loss of interest and energy, depressed mood, fluctuations in sleep or eating patterns, reduced ability to think or concentrate, feelings of worthlessness, and recurrent suicidal ideation. The symptoms of depressed mood or loss of interest are required and must be present for a minimum of 2 weeks to assign a diagnosis of major depressive disorder.^2-4^ PND should not be confused with the less severe “postpartum blues,” which is a commonly experienced, transient mood disturbance consisting of crying, irritability, fatigue, and anxiety usually resolving within the 10 days following delivery.^3^

## Prevalence of Perinatal Depression

Depression, in general, is a common mental health disorder in the United States. In 2016, 6.7 percent of adults in the United States ages 18 years or older had experienced at least one major depressive episode in the previous year.^5,^ ^6^ The estimated prevalence of depression among pregnant and postpartum women was 9.1 and 10.2 percent, respectively, according to the 2004 to 2005 National Epidemiology Survey on Alcohol and Related Conditions.^7^ A 2015 literature review identified three relatively recent studies reporting prevalence of major depressive disorder in postpartum women in the United States; estimates ranged from 8.9 percent in the first month postpartum to 14.9 percent at any point in the first year postpartum.^8^ Further, a recent analysis of the 2012 Pregnancy Risk Assessment Monitoring System (PRAMS) survey found that 11.5 percent of new mothers self-reported postpartum depressive symptoms (“always” or “often” feeling down, depressed, or hopeless, or having little interest in doing things). The subgroups with the highest rates across a number of categories are: women who were aged 19 years or younger (18.3%, vs. 6.8% to 11.5% among age 20 and older), American Indian/Alaska Natives (17.5%, vs. 8.6% to 14.0% for other race/ethnic groups), those with less than 12 years of education (13.4%, vs. 8.0% with more than 12 years of education), unmarried women (12.7%, vs. 11.5% in married women), and those with six to 13 stressful life events in the previous 12 months (24.2%, vs. 8.0% to 14.4% with 0–5 events).^9^ A separate cohort study found that 42% of women who reported mood symptoms at 3 months postpartum had also experienced mood symptoms during pregnancy, suggesting that onset during pregnancy is fairly common, among those with postpartum symptoms.^10^

## Burden of Perinatal Depression

It is well established that depression during the postpartum period can have negative effects on the mother and child. Although acts of harming oneself or others during PND remain rare, depression increases the risk of suicide and suicidal ideation among postpartum women,^11^ and depressed mothers have reported more thoughts of harming their infants than nondepressed mothers.^12^ A 2000 meta-analysis of 46 observational studies found women with PND exhibited significantly higher levels of negative maternal behaviors (i.e., negative maternal affect and hostile/coercive behaviors) and disengagement from their infants than nondepressed mothers.^13^ They were also more likely to exhibit significantly lower levels of positive maternal behaviors (e.g., play, praise).^13^ An earlier meta-analysis of 19 studies also found PND to have a statistically significant negative effect on maternal interactive behavior, infant interactive behavior and dyadic interactive behavior.^14^ In addition, depression during pregnancy increases the risk of preterm birth and small-for-gestational-age, and may also increase the risk of low birthweight.^15^ A cohort study in Brazil that interviewed 4231 women during pregnancy and 3 months postpartum found that, at age six, their children were at increased risk of psychiatric disorders, both among those who reported symptoms of anxiety and depression during pregnancy (19.8% versus 11.1% for women without symptoms) and postpartum (21.7% versus 10.8%).^10^ Results remained statistically significant even when controlling for mood symptoms during the other phase, suggesting depression during pregnancy and the postpartum phase each may be independently detrimental to the child’s future mental health.

Postpartum depression can negatively affect children’s health and development. Among 5,565 families enrolled in the Healthy Steps for Young Children, 17.8 percent of mothers reported depressive symptoms during the first 2 to 4 months of delivery.^16^ Their infants received fewer preventive health services (e.g., vaccinations) than infants of nondepressed mothers.^16^ Additionally, a recent analysis of the PRAMS survey found that women with postpartum depression are at risk for early breastfeeding cessation compared with mothers without depressive symptoms.^17^ Depressed mothers are also more likely to engage in smoking and not place their children in car seats as frequently.^18^

## Risk Factors and Etiology for Perinatal Depression

There are a multitude of risk factors thought to be associated with the development of PND. These can include a past history of depression,^19-22^ history of physical or sexual abuse,^20^ unplanned/unwanted pregnancy,^23^ stressful life events,^9,^ ^20,^ ^24^ lack of social and financial support,^20,^ ^21,^ ^23^ intimate partner violence,^25,^ ^26^ pregestational or gestational diabetes,^27^ and complications during pregnancy (e.g., hyperemesis, premature contractions).^28^ Additionally, low socioeconomic status, lack of social support, and bearing children during adolescence have been shown to increase women’s risk of developing PND after delivery.^29^ Genetic factors are also suspected to contribute to women’s risk of developing PND, a hypothesis that has been supported by recent epidemiological studies conducted within families, although more research is needed to make firm conclusions.^4,^ ^30,^ ^31^

The causes of PND are likely multifactorial and include social, psychological, biological, and genetic factors. Genetic influence is supported by epidemiological studies conducted among families.^4,^ ^30^ A 2006 study conducted in the United Kingdom evaluated 44 pairs of sisters who had a history of unipolar depression and found that among those pairs in which one sister had been diagnosed with PND according to DSM-IV, 42 percent of the other sisters developed PND as well.^32^ For those who did not have a sister who experienced PND, the rate of PND diagnosis was only 15 percent (p=0.01). Additionally, a study of a subset of 328 women of childbearing age who were part of the Genetics of Recurrent Early-Onset Depression data set with at least one sibling who was also part of the data set showed similar results. They found that diagnosis of PND in one sibling was associated with a significantly increased risk of a diagnosis of PND in the other sibling (odds ratio [OR], 3.96 [95% confidence interval (CI), 1.51 to 10.42; p=0.005]).^31^ These studies, however, have limitations in their design, including relying on retrospective oral report or chart review, failing to control for comorbid psychiatric illnesses, and a failure to evaluate possible confounding of environmental factors.^30^ This has highlighted the importance of assessing the role of well-defined genetic markers in the development of PND.

Because hormones have long been suspected of contributing to the onset of PND, research into genes involved in the regulation or uptake of hormones has substantially increased. Two types of genes—estrogen receptor genes and genes involved in the synthesis or metabolism of the brain monoamines dopamine and serotonin—have been of particular interest to researchers.^30,^ ^33,^ ^34^ In addition, dysregulation in hormones during the peripartum period has long been suspected of contributing to the onset of PND. Oxytocin and the hormones involved in the regulation of the hypothalamic-pituitary-adrenal (HPA) axis, namely estrogen, progesterone, and corticotropin-releasing hormone, have garnered interest,^4,^ ^29,^ ^35,^ ^36^ but more research needs to be done to confirm this relationship.

## Interventions to Prevent Perinatal Depression

A variety of counseling and pharmacologic interventions are available to treat PND,^37^ and due to their effectiveness, some have been proposed and evaluated as a method to target the prevention of PND when applied during pregnancy or in the immediate postpartum period (within 12 weeks). Counseling interventions to prevent PND include professionally based home visitation to provide emotional support or counseling (and sometimes including practical house- and child-care support as well),^38^ peer support by women who have previously experienced PND,^39^ cognitive behavioral therapy (CBT),^40^ interpersonal psychotherapy,^41,^ ^42^ nondirective counseling (focused on listening and support rather than giving advice), and debriefing (talking about the childbirth experience and its emotional/psychological impact on the women).^43,^ ^44^ Pharmacologic interventions include first- and second-generation antidepressants (Appendix B)^45,^ ^46^ and hormonal therapy^47,^ ^48^ administered during pregnancy or immediately after delivery; however, because of the potential harms of fetal, neonatal, or infant exposure to medications, studies on their use has been limited among pregnant and postpartum persons. Various complementary and alternative therapies have also been evaluated to prevent PND including hypnosis^49^ and dietary supplements (e.g., omega-3 fatty acids,^50,^ ^51^). Healthy lifestyle interventions such as increasing exercise during and after pregnancy have also been evaluated, as well as pre- and postnatal education classes to prepare mothers and fathers for parenthood.^52-55^ The interventions may target specific subpopulations such as those who are at an increased risk for PND (e.g., adolescents, persons with a history of depression or PND)^1^ and may vary by setting, intensity, format (e.g., group-based), delivery (e.g., web-based, telephone-based), and interventionist (e.g., midwife, psychologist).

## Current Clinical Practice and USPSTF Recommendations

There are no current guidelines on how to prevent PND, and no prior U.S. Preventive Services Task Force (USPSTF) recommendation on this topic. In 2015, the USPSTF recommended screening for depression in the general adult population including pregnant and postpartum women, and said screening should be implemented with adequate systems in place to ensure accurate diagnosis, effective treatment, and appropriate followup (B recommendation).^56^ The USPSTF concluded with at least moderate certainty that there is a moderate net benefit to screening for depression in pregnant and postpartum women who receive care in clinical practices that have cognitive behavioral therapy or other evidence-based counseling available after screening.^56^ Other guidelines on the topic of PND similarly focus specifically on screening and treatment of PND, not primary prevention.^57,^ ^58^ We found no studies that provided information about what approaches are used in real-life clinical practice for preventing PND, and likely include some combination of close monitoring, referral to a counselor or social worker, and prophylactic use of antidepressants (particularly in individuals who stopped taking antidepressants during pregnancy but were experiencing symptoms), and likely varies substantially.