# Appendix I Ongoing Studies

Trial identifier | Study Name | Location | Estimated N Age range | Intervention | Outcome Measures | Status
NCT02818075 | Mobile Phone Based Peer Support to Prevent Postpartum Depression Among Adolescent Mothers | Canada | 40 16–24 years | Mobile Phone Based Peer Support vs Usual Care | Feasibility as assessed by the Participant Eligibility Assessment Form \| Acceptability as assessed by the validated Peer Support Evaluation Inventory \| Compliance as assessed by the Activity Log Form \| Support strategies as assessed by the Activity Log Form \| Edinburgh Postnatal Depression Scale \| State-Trait Anxiety Inventory (STAI) \| Short Form Social Support Questionnaire (SSQ6) \| Health Services Utilization Questionnaire | Recruiting Start date: Apr 2016 Est completion date: Dec 2016
NCT02323152 | Prevention of postpartum depression development in women with very high risk (PROGEA) | Spain | 135 18–60 years | Psychoeducation vs Standard care | Depression Scale \| Vulnerable personality \| Physical Activity Questionnaire \| Temperament Style | Unknown status Start date: Sep 2012 Est completion date: Sep 2016
NCT02121015 | Online Collaborative Learning Intervention to Prevent Perinatal Depression | United States | 210 18+ years | E-intervention with group vs Self-Directed use of e-intervention | Change in depression symptoms over time as measured by the Inventory of Depression and Anxiety Symptoms (IDAS) \| Usability and satisfaction based on the USE measure \| Diagnosis of Major Depressive Disorder based on the Mini International Neuropsychiatric Interview (MINI) \| Site usage as measured by the number of logins to the site over the course of the intervention | Active, not recruiting Start date: May 2016 Est completion date: Jul 2017
JPRNUMIN000020790 | Antenatal couplebased parenting support for preventing postpartum depression: Clinical application and evaluation of the program | Japan | 30 couples NR | Couple antenatal session and information via mail vs usual care | Edinburgh Postnatal Depression Scale at one and a half months after the expected date of delivery | Completed Start date: Jan 2016 Est completion date: Mar 2017
NCT01883479 | Effect of Exercise and Wellness Interventions on Preventing Postpartum Depression (HM2) | United States | 450 21–45 years | Telephone support with support for Exercise or Wellness vs Usual care | Depression \| Depressive Symptoms | Completed Start date: Dec 2012 Est completion date: May 2017
NCT01482832 | Interpersonal Therapy-Based Treatment to Prevent Postpartum Depression in Adolescent Mothers (REACH 2) | United States | 250 12–19 years | Interpersonal therapy-based treatment vs Standard care | Diagnosis of depression \| Degree of depressive symptoms | Active, not recruiting Start date: Dec 2011 Est completion date: Apr 2018
NCT02843022 | Effectiveness of a Web-based Nursing Intervention in the Reduction of Postpartum Depression and Parenting Stress. (Enhancing Follow-up Mechanisms for Women at Risk for Postpartum Depression) | United States | 683 18+ years | Usual care vs Usual care + Text messages vs Text messages + nurse phone call if requested | postpartum depression symptoms \| breastfeeding outcomes \| patient satisfaction/experience \| Parenting stress | Active, not recruiting Start date: Nov 2015 Est completion date: Feb 2018
NCT02505984 | Preventing Postpartum Depression With Intranasal Oxytocin (IN-OXT) | United States | 90 18–50 years | Oxytocin vs Placebo | Depression symptoms \| Mother-infant bonding \| Posttraumatic stress symptoms \| Child development | Recruiting Start date: Oct 2015 Est completion date: Dec 2019
NCT03024645 | Be a Mom: Effectiveness of a Web-based Preventive Intervention for Postpartum Depression (BeAMom) | Portugal | 1000 18–50 years | Web-based CBT (Be A Mom) vs Usual care Web-based CBT with partner (Be A Mom) vs Usual care | Number of women with clinically significant postpartum depressive symptoms (EPDS > 12) at 4 months postpartum \| Number of women with clinically significant postpartum depressive symptoms (EPDS > 12) at 12 months postpartum \| Changes from baseline in the severity of depressive symptoms \| Changes from baseline in anxiety symptoms \| Changes from baseline in quality of life \| Changes from baseline in dyadic adjustment \| Changes from baseline in maternal confidence \| Changes from baseline in the frequency of negative automatic thoughts \| Changes from baseline in psychological flexibility \| Changes from baseline in self-criticism and selfcompassion \| Changes from baseline in emotional regulation \| Acceptability of the program for postpartum women \| Feasibility of the program for postpartum women as measured by number of website logins \| Feasibility of the program for postpartum women as measured by website average visit length \| Feasibility of the program for postpartum women as measured by number of exercises completed \| Feasibility of the program for postpartum women as measured by dropout rate. | Enrolling by invitation Start date: Aug 2017 Est completion date: Jun 2019
NCT02833519 | Effect of Group Exercise on Mental Wellbeing Among Pregnant Women at Risk of Perinatal Depression: A Randomized Controlled Clinical Trial | Denmark | 300 18+ years | Group exercise vs Usual care | World Health Organisation Five Well-being Index (WHO-5). \| Edinburgh Postnatal Depression Scale (EPDS) \| The 12-item General Health Questionnaire (GHQ-12) \| Spielbergers State Anxiety Inventory (STAI) \| Pittsburgh Sleep Quality Index (PSQI) \| Percentage of participants with sick leave \| Episodes of hospitalization, measured in number of hospitals admissions \| Hospitalization, length of stay \| Percentage of participants with respectively spontaneous onset of labor or inducted labor \| Use of epidural anaesthesia \| Duration of labor \| Mode of delivery. Percentage of participants with respectively spontaneous delivery, vacuum extraction or cesarean section \| Birth weight in kilograms \| Birth length in centimeters | Enrolling by invitation Start date: Aug 2016 Est completion date: Mar 2019
NCT02791932 | Effect of Exercise on Perinatal Depression | United States | 200 18+ years | Exercise vs Usual care | Edinburgh Postnatal Depression Scale \| Postpartum Weight Retention | Recruiting Start date: NR Est completion date: Oct 2019
ISRCTN14864 807 | Telephone-based peer support intervention programme for prevention of postnatal depression | Singapore | 118 21+ years | Peer support vs Usual care | Postnatal depression is measured using Edinburgh Post Natal Depression Scale and Patient Health Questionnaire at recruitment (baseline), 4 weeks and 12 weeks postpartum 1. Anxiety is measured using State Trait Anxiety Inventory at recruitment (baseline), 4 weeks and 12 weeks postpartum 2. Loneliness is measured using UCLA Loneliness Scale at recruitment (baseline), 4 weeks and 12 weeks postpartum 3. Social support is measured using Perceived Social Support for Parenting (PSSP) at recruitment (baseline), 4 weeks and 12 weeks postpartum | Ongoing Start date: Jul 2017 Est completion date: NR
JPRNUMIN000029978 | Evaluation of early nursing intervention program to prevent postpartum depression for couples | Japan | 300 20+ years | Nursing intervention vs usual care | EPDS, K6, PDPI-R, ECR-GO | Not yet recruiting Start date: Dec 2017 Est completion date: NR
NCT03283254 | PREPP: Preventing Postpartum Depression (PREPP) | United States | 300 18–45 years | Practical Resources for Effective Postpartum Parenting vs Enhanced Treatment As Usual | Postpartum Depression Symptoms \| Infant Behavior | Recruiting Start date: Oct 2017 Est completion date: NR
NCT02760004 | PRogram In Support of Moms: An Innovative Stepped-Care Approach for Obstetrics and Gynecology Clinics (PRISM) | United States | 300 18–55 years | Access to MCPAP for Moms plus stepped care implementation support vs Enhanced usual care | EPDS, Mental Health Utilization Questionnaire | Recruiting Start date: Apr 2016 Est completion date: Sep 2019

Abbreviations: EPDS = Edinburgh Postnatal Depression Scale; EST = estimated; NR = not reported; PDPI = Postpartum Depression Predictors Inventory; vs = verse