# Appendix H Accuracy of Screening Instruments to Predict Perinatal Depression

Austin and Lumley^129^ summarized 16 studies investigating prenatal tools for predicting postpartum depression, including the Beck Depression Inventory, Edinburgh Postnatal Depression Scale (EPDS), Eysenck Personality Inventory, General Health Questionnaire, Schedule for Affective Disorders and Schizophrenia, Spielberger State/Trait Anxiety Scale, Spanier Dyadic Adjustment Scale, Sarason Social Support Scale, and the Social Support Questionnaire. The authors concluded that none of the screening instruments were appropriate for routine use during pregnancy. Many of the studies, they found, had insufficient sample sizes, utilized tools that had not been validated for use in the study population (e.g., use of a postpartum measure in pregnant women), or did not provide sufficient information about the psychometric properties of the tool or how it had been developed. Additionally, cutoff scores varied considerably across studies.

Appendix H Table 1 summarizes the five studies published since 2003 that have investigated the ability of tools used during the prenatal or early postpartum period to predict subsequent development of postpartum depression. Most of these studies utilized self-report instruments, primarily the EPDS.^119,^ ^130-133^ All five of the studies reported that EPDS scores during the prenatal or early postpartum period (2–7 days postpartum) were predictive of depressive symptoms later in the postpartum period. In terms of the EPDS predicting future depression, the studies reported sensitivity ranging from 67 to 85 percent, specificity ranging from 65 to 95 percent, and positive predictive value (PPV) ranging from 43 to 67 percent. The EPDS cutoff scores varied considerably across the five studies—from >8 to >15 (with higher scores indicating more symptomatology)—and the timing of outcomes assessment ranged from 4 to 8 weeks postpartum. One study^130^ assessed women at two postpartum time points and reported that EPDS scores at 1 week postpartum were predictive of future EPDS scores at both 4 weeks (OR 30.3, 95% CI, 17.5 to 42.3) and 8 weeks (OR 19.1, 95% CI 11.0 to 32.9) postpartum. Four of the five studies used the EPDS to assess depressive symptoms at both baseline and followup. Only one study^119^ utilized a clinician-administered diagnostic interview to assess depressive symptoms at followup; it found that EPDS scores at 3–5 days postpartum were predictive of a diagnosis of major or minor depression at 8 weeks postpartum (sensitivity 82%, specificity 95%).

The remaining self-report instruments were the Antenatal Risk Questionnaire (ARQ),^134^ Antenatal Psychosocial Questionnaire (APQ),^131^ Postpartum Adjustment Scale (PDS),^135^ Postpartum Depression Predictors Inventory-Revised (PDPI-R),^136^ Predictive Index of Postnatal Depression (PIPD),^137^ Pregnancy Risk Questionnaire (PRQ),^138^ and the Swedish Universities Scale of Personality (SSP).^139^ All instruments but the APQ were predictive of future symptoms of depression in the postpartum period, albeit many findings were quite modest and require replication. Sensitivity of these instruments ranged from 44 (PRQ) to 76 percent (PDPI-R), specificity ranged from 46 (PDPI-R) to 92 percent (PRQ), and PPV ranged from 23 (PIPD) to 37 percent (PAQ). Only one item on the APQ predicted postpartum depression: emotional abuse as a child (OR 15.24, 95% CI, 1.36 to 171.32).

Two studies investigated the utility of a clinician tool, the Brisbane Postnatal Depression Index (BPDI), to predict future depression symptoms at 4 months postpartum.^140,^ ^141^ The first portion of the BPDI is administered at the “booking in visit” (typically by 10 weeks’ gestation), the second portion at 3 days postpartum (or before discharge from hospital). The index also incorporates data from several self-administered questionnaires, including the Maternity Social Support Scale, the Royal Women’s Hospital Patient Satisfaction Form, the Kennerly Blues Scale, and the Brisbane Mother Baby Scale score. These two studies reported sensitivity ranging from 36 to 47 percent, specificity from 88 to 92 percent, PPV at 40 percent, and NPV at 91 percent. While this index shows promise in identifying women at risk for postpartum depression, collating data from multiple timepoints and sources could prove burdensome to the clinician. Furthermore, the authors concluded that the sensitivity and specificity of this instrument require improvement prior to utilizing it as a routine measure of prediction.^141^

One study utilized the anxiety modules of the Mini International Diagnostic Interview for DSM-IV, a structured interview administered by a clinician, to assess for diagnoses of generalized anxiety, social phobia, obsessive-compulsive disorder, agoraphobia, panic disorder, and post-traumatic stress disorder during the third trimester of pregnancy.^142^ They reported that women with anxiety disorders during pregnancy were more likely to experience depression symptoms at 6 weeks postpartum (aOR 2.7, 95% CI, 1.1 to 6.3), even after adjusting for major depression symptoms during pregnancy.

Appendix H Table 2 summarizes several intervention studies included in the main review that utilized a variety of screening methods to identify women at risk for developing postpartum depression, including the Center for Epidemiologic Studies Depression Scale (CES-D), Cooper Survey Questionnaire (CSQ), EPDS, Leverton Questionnaire, PIPD, and the Riguetti-Veltema Interview. For the purposes of this contextual question, the most relevant data are the depression outcomes of the women identified as high risk due to elevated depressive symptoms at baseline who were not exposed to an intervention intended to prevent postpartum depression (i.e., the control participants). In control participants, incidence of depressive episodes or presence of elevated postpartum depression symptoms were observed in 10 to 33 percent in women identified as high risk based on CES-D baseline cutoff score of 16 or a history of depression.^38,^ ^79,^ ^83,^ ^84^ Twenty to 31 percent using a CSQ cutoff of 27,^42,^ ^87^ 25 to 52 percent using an EPDS cutoff of 9,^77,^ ^105^ 10 percent using an LQ cutoff of 11,^93^ 9 to 21 percent using a PIPD cutoff of 15,^95^ and 45 percent using a Riguetti-Veltema cutoff of 3.^89^

In summary, the EPDS and the CES-D appear to be the most commonly utilized tools for identifying women at risk for developing postpartum depression. Many of the same limitations noted in the Austin and Lumley review^129^ carry over to the literature published since that time. While many other patient- or clinician-administered tools have also shown promise, additional research is required to support the use of these tools in routine clinical practice. Finally, it is important to note that this contextual question was not reviewed systematically; included studies were not formally rated for quality and some relevant studies may have been excluded inadvertently.

Appendix H Table 1 Studies That Have Investigated the Ability of Tools Used During Prenatal or Early Postpartum Period to Predict Subsequent Development of Postpartum Depression

Author | N | Predictor (Cut-off Score) | Type | Baseline Timepoint | Outcome (Cut-off Score) | Outcome Timepoints | Summary of Results
Austin, 2013^134^ | 1196 | ANRQ (≥23) | Self-administered | 32 weeks gestation | CIDI (diagnosis of major depression) | 2 or 4 months postpartum | ANRQ scores in late pregnancy were predictive of major depression at 2 or 4 months postpartum (sensitivity 62%, specificity 64%, PPV 30%, OR 6.3, 95% CI, 3.5–11.5).
Austin, 2005^138^ | 1296 | PRQ (≥46) | Self-administered | 32 weeks gestation | CIDI (diagnosis of major depression) | 2 or 4 months postpartum | PRQ scores in late pregnancy were predictive of depression symptoms at 2 or 4 months postpartum (sensitivity 44%, specificity 92%, PPV 24%, OR 9.18, 95% CI NR).
Beck, 2006^136^ | 139 | PDPI-R (>10.5) | Self-administered | Third trimester | EPDS (NR) | 2 and 6 months postpartum | PDPI-R scores in late pregnancy were predictive of depression symptoms at 2 and 6 months postpartum (sensitivity 76%, specificity 46%). Data for other cutoff scores available in Beck 2006 Table 3.
Davis, 2008^135^ | 200 | PAQ (≥4) | Self-administered | Postdelivery (hospital) | PDSS (≥80) | 6 weeks postpartum | PAQ scores post-delivery were predictive of depression symptoms at 6 weeks postpartum (PPV 37%, NPV 90%). Correlation between the baseline and outcome measures was moderate (0.28).
Dennis, 2004^130^ | 594 | EPDS (>9) | Self-administered | 1 week postpartum | EPDS (>9) | 4 and 8 weeks postpartum | EPDS scores at one week postpartum were predictive of depression symptoms at 4 weeks (sensitivity 83%, specificity 86%, PPV 64%, NPV 94%; OR 30.3, 95% CI 17.5–42.3) and 8 weeks (sensitivity 79%, specificity 83%, PPV 55%, NPV 94%; OR 19.1, 95% (CI 11.0–32.9) postpartum. Data for >12 cutoff scores also available in Dennis 2004, Table 1.
Edwards, 2008^131^ | 154 | EPDS (≥10), APQ (NR) | Self-administered | Antenatally, not otherwise specified | EPDS (≥10) | 6 weeks postpartum | Women who met case criteria for depression antenatally were significantly more likely to also meet criteria for postnatal depression (chi-square = 22.72, p = 0.000). Only one item on the APQ predicted postnatal depression: emotional abuse as a child (OR 15.24, 95% CI, 1.36–171.32).
Honey, 2003^137^ | 306 | PIPD (≥ 27) | Self-administered | Third trimester | EPDS (≥13) | 6 weeks postpartum | PIPD scores in late pregnancy were predictive of depression symptoms at 6 weeks postpartum (sensitivity 51%, specificity 79%, PPV 23%).
Iliadis, 2015^139^ | 1037 | SSP (NR) | Self-administered | Late pregnancy | EPDS (≥12), DSRS (met DSM-IV criteria for depression) | 6 weeks and 6 months postpartum | Neuroticism scores during late pregnancy were associated with increased depression symptoms at 6 weeks postpartum (aOR = 3.4, 95% CI, 1.8–6.5 and 6 months postpartum (aOR = 3.9, 95% CI, 1.9–7.9). Somatic trait anxiety scores during late pregnancy were associated with increased depression symptoms at six weeks postpartum (aOR = 2.1, 95% CI, 1.2–3.5). Psychic trait anxiety scores during late pregnancy was associated with increased depression symptoms at six weeks postpartum (aOR = 1.9, 95% CI, 1.1–3.1). Mistrust scores during late pregnancy were associated with increased depression symptoms at six months postpartum (aOR 1.9, 95% CI, 1.1–3.4)
Ingram, 2007^132^ | 118 | EPDS (≥ 13/≥ 15) | Self-administered | 30–36 weeks gestation | EPDS (≥13) | 6 weeks postpartum | EPDS scores during late pregnancy were predictive of depression symptoms at 6 weeks postpartum. Cutoff of 13: sensitivity 67%, specificity 90%, PPV 35%, OR 17.82 (95% CI, 3.90–81.4). Cutoff of 15: sensitivity 67%, specificity 97%, PPV 67%, OR 70.67 (95% CI, 11.7–427).
Jardri, 2006^119^ | 363 | EPDS (> 8) | Self-administered | 3–5 days postpartum | MINI (diagnosis of major or minor depression) | 8 weeks postpartum | EPDS scores at 3–5 days postpartum were predictive of depression diagnoses at 8 weeks postpartum (sensitivity 82%, specificity 95%, PPV 43%).
SutterDallay, 2004^142^ | 497 | MINI (DSM-IV diagnoses of generalized anxiety, social phobia, obsessivecompulsive disorder, agoraphobia, panic disorder, post-traumatic stress disorder) | Clinician structured interview | Third trimester | EPDS (>12) | 6 weeks postpartum | Women with anxiety disorders during pregnancy were more likely to experience postpartum depression symptoms at 6 weeks than women without anxiety disorders (aOR 2.7, 95% CI, 1.1–6.3).
Teissedre, 2004^133^ | 1154 | EPDS (≥ 10) | Self-administered | 2–3 days postpartum | EPDS (>10) | 4–6 weeks postpartum | EPDS scores at 2–3 days postpartum were predictive of depression symptoms at 4–6 weeks postpartum (sensitivity 85%, specificity 64%, PPV 54.4%). Data for other cutoff scores available in Teissedre 2004, Table 3.
Webster, 2003^140^ | 1762 | BPDI (≥ 6) | Clinician tool | 3 days postpartum | EPDS (>12) | 4 months postpartum | Index scores at 3 days postpartum were predictive of depression symptoms at 4 months postpartum (sensitivity 36.3%, specificity 92%, PPV 39.8%, NPV 90.8%). Data for other cutoff scores available in Webster 2003 Table 4.
Webster, 2006^141^ | 353 | BPDI (≥ 6) | Clinician tool | Postdelivery (hospital) | EPDS (>12) | 4 months postpartum | Index scores at thre3e days postpartum were predictive of depression symptoms at 4 months postpartum (sensitivity 47.5%, specificity 88.5%, PPV 39.6%, NPV 91.4%).

Abbreviations: ANRQ = Antenatal risk questionnaire; aOR = adjusted odds ratio; APQ = Antenatal Psychosocial Questionnaire; BPDI = Brisbane Postnatal Depression Index; CESD = Center for Epidemiologic Studies Depression scale; CI = confidence interval; CSQ = Cooper Survey Questionnaire; DSM-IV = DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, fourth version; DSRS = Depression Self-Rating Scale; EPDS = Edinburgh Postnatal Depression Scale; MDE = major depressive episode; MINI = Mini International Neuropsychiatric Interview; MMS = maternal mood screener; NR = not reported; NPV = negative predictive value; OR = odds ratio; PAQ = Postpartum Adjustment Questionnaire; PDPI-R = Postpartum Depression Predictors Inventory-Revised; PIPD = Predictive Index of Postnatal Depression; PPV = positive predictive value; PRQ = Pregnancy Risk Questionnaire; SCID = Structured Clinical Interview; SSP = Swedish Universities Scale of Personality

Appendix H Table 2 Summary of Included Studies That Utilized Screening Methods to Identify Women at Risk for Developing Postpartum Depression

High-Risk Criteria (Cut-off Score) | Author | N | Type | Baseline Timepoint | Outcome Timepoints | Outcome | Depression incidence CG % | Depression incidence IG %
CES-D (≥ 16) or past history of major depressive episode | Munoz, 2007^83^ | 41 | Self-administered | 12–32 weeks gestation | 12 months postpartum | MMS (diagnosis of major depressive episode) | 25% | 14%
CES-D (≥ 16) or a personal of family history of depression | Le, 2011^84^ | 217 | Self-administered | ≤ 24 weeks gestation | 12 months postpartum | MDE Screener (diagnosis of major depressive episode) | 10% | 8%
CES-D (> 16) or a lifetime depressive episode, but not currently meeting criteria for depression | Tandon, 2011^79^ | 61 | Self-administered | Pregnancy to 6 months postpartum | 3 months postintervention | MMS (diagnosis of major depressive episode) | 33% | 9%
CES-D (≥ 16) or a lifetime depressive episode, but not currently meeting criteria for depression | Tandon, 2014^24^ | 78 | Self-administered | Pregnancy to 6 months postpartum | 6 months postintervention | SCID-I (diagnosis of major depressive episode) | 32% | 15%
CSQ (> 27) and not currently depressed | Zlotnick, 2006^87^ | 99 | Self-administered | 23–32 weeks gestation | 3 months postpartum | LIFE (NR) | 20% | 4%
CSQ (≥ 27) and not currently depressed | Zlotnick, 2016^42^ | 205 | Self-administered | 20–35 weeks gestation | 6 months postpartum | LIFE (>5 two weeks in a row) | 31% | 16%
EPDS (> 9) | Dennis, 2003^105^ | 42 | Self-administered | 8–12 weeks postpartum | 4 and 8 weeks post-randomization | EPDS (>12) | 41% at 4 weeks; 52% at 8 weeks | 10% at 4 weeks; 15% at 9 weeks
EPDS (> 9) | Dennis, 2009^77^ | 701 | Self-administered | 0–2 weeks postpartum | 12 weeks postpartum | EPDS (>12) | 25% | 14%
LQ (> 11) | Kozinsky, 2012^93^ | 324 | Self-administered | Second trimester | 6–8 weeks postpartum | LQ (≥12) | 10% | 5%
PIPD (> 15) | Cooper, 2015^95^ | 301 | Self-administered | 20 weeks gestation | 8 weeks to 18 months postpartum | SCID (diagnosis of major depressive episode) | 9%-21% | 4–26%
Riguetti-Veltema Interview (≥ 3) | Ortiz Collado, 2014^89^ | 184 | Interview | ≤ 20 weeks gestation | 5–12 weeks postpartum | EPDS (≥12) | 45% | 34%

Abbreviations: CESD = Center for Epidemiologic Studies Depression scale; CG = control group; CSQ = Cooper Survey Questionnaire; DSM-IV = DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, fourth version; DSRS = Depression Self-Rating Scale; EPDS = Edinburgh Postnatal Depression Scale; IG = intervention group; LIFERIFT = Range of Impaired Functioning Tool; LQ = Leverton Questionnaire; MDE = major depressive episode; MINI = Mini International Neuropsychiatric Interview; MMS = maternal mood screener; NR = not reported; SCID = Structured Clinical Interview