# Appendix G Depression Symptom Severity Scales

Instrument | Number of Items | Scoring Range | Administration Time | Typical Cut-Points
Beck Depression Inventory (BDI/BDI-II) | 21 | 0–63 | 10 minutes | 11 = mild 17 = borderline clinical 21 = moderate 31 = severe 40 = extreme
Center for Epidemiologic Studies Depression Scale (CES-D) | 20 | 0–60 | 10 minutes | 16
Edinburgh Postnatal Depression Scale (EPDS) | 10 | 0–30 | 5 minutes | 0–9 = mild distress 10–12 = moderate distress 13 = high likelihood of diagnosis
General Health Questionnaire (GHQ) | 60 (full questionnaire) | Varied | 6–8 minutes | Varied
Geriatric Depression Scale (GDS Long Form) | 30 | 0–30 | 5 minutes | 0–9 = normal 10–19 = mild 20–30 = severe
Geriatric Depression Scale, 15 item (GDS Short Form) | 15 | 0–15 | 5–7 minutes | ≥ 6
Hamilton Depression Rating Scale (HDRS/HAM-D) | 17 | 0–54 | 15 minutes | 7–17 = mild 18–24 = moderate ≥24 = severe
Hospital Anxiety and Depression Scale (HADS) | 14 (7 specific to depression) | 0–21 | 2–5 minutes | ≥ 8
Leverton Questionnaire (LQ) | 24 | 0-48 | NR | 11–14 = risk of minor depression 15+ = risk of major depression
Montgomery-Asberg Depression Rating Scale (MADRS) | 10 | 0–60 | 15 minutes | 15 = mild 25 = moderate 31 = severe 44 = very severe
Patient Health Questionnaire–Depression (PHQ-9) | 9 | 0–27 | 5–10 minutes | <5 = minimal 5–9 = mild 10–14 = moderate 15–19 = moderately severe 20–27 = severe
Profile of Mood States (POMS) | 65 The depression subscale (POMS-D) contains 15 items | 0–60 | 8–10 minutes | Not established
Symptom Checklist (SCL-90-r) | 90 | NR | 12–15 minutes | NR

Abbreviations: NR = not reported