# Appendix F Additional Evidence Tables

Appendix F Table 1 Characteristics of Included Studies, by Author

Appendix F Table 2 Detailed Population Characteristics, by Author

Appendix F Table 3 Intervention Characteristics Overview, by Author

Appendix F Table 4 Detailed Intervention Characteristics, by Intervention Category

Appendix F Table 5 Dichotomous Outcome Score Results (All), by Author

Appendix F Table 6 Continuous Mental Health Outcome Score Results, by Outcome

Appendix F Table 7 Other Continuous Outcome Score Results, by Outcome