# Appendix E Additional Figures

Appendix E Figure 1 Forest Plot of Depression Incidence, Prevalence, or Exceeding a Symptom Cut-Off for Counseling, Health System, and Physical Activity Interventions, Showing Population Selection and Intervention Focus

Note: For followup time, “g” indicates during gestation and “p” indicates postpartum; thus, for example, g37=37 weeks’ gestation and p12=12 weeks postpartum

Abbreviations: BDI = Beck Depression Inventory; CBT = cognitive behavioral therapy; CES-D = Center for Epidemiologic Studies Depression Scale; CI = confidence interval; Depr = depression; EPDS = Edinburgh Postnatal Depression Scale; g = weeks’ gestation; IPT = interpersonal therapy; LQ = Leverton Questionnaire; MT = mindfulness therapy; Oth = other; p = weeks postpartum; PA = physical activity; Prev = prevalence; RR = relative risk

This figure is a forest plot of depression incidence, prevalence, or exceeding a symptom cut-off for counseling, health system, and physical activity interventions, showing population selection and intervention focus..

Appendix E Figure 2 Forest Plot of Depression Incidence, Prevalence, or Exceeding a Symptom Cut-Off for Other Behavior-Based Interventions, Showing Population Selection and Intervention Focus

Note: For followup time, “g” indicates during gestation and “p” indicates postpartum; thus, for example, g37=37 weeks’ gestation and p12=12 weeks postpartum

Abbreviations: BDI = Beck Depression Inventory; CBT = cognitive behavioral therapy; CES-D = Center for Epidemiologic Studies Depression Scale; CI = confidence interval; Depr = depression; EPDS = Edinburgh Postnatal Depression Scale; g = weeks’ gestation; IPT = interpersonal therapy; LQ = Leverton Questionnaire; MT = mindfulness therapy; Oth = other; p = weeks postpartum; PA = physical activity; PPD = postpartum depression; Prev = prevalence; RR = relative risk

This figure is a forest plot of depression incidence, prevalence, or exceeding a symptom cut-off for other behavior-based interventions, showing population selection and intervention focus.

Appendix E Figure 3 Forest Plot of Depression Incidence, Prevalence, or Exceeding a Symptom Cut-Off for Antidepressants and Supplements, Showing Population Selection and Intervention Focus

Note: For followup time, “g” indicates during gestation and “p” indicates postpartum; thus, for example, g37=37 weeks’ gestation and p12=12 weeks postpartum

Abbreviations: CI = confidence interval; DHA = Docosahexaenoic acid; EPA = Eicosapentaenoic Acid; g = weeks’ gestation; p = weeks postpartum; RR = relative risk

This figure is a forest plot of depression incidence, prevalence, or exceeding a symptom cut-off for antidepressants and supplements, showing population selection and intervention focus.