# Appendix D Excluded Studies

Reason for Exclusion^*^
E1. Study Relevance
E2. Setting: Emergency department; schools classroom-based; Inpatient; Institutional/Residential; Workplace; Churches; Military; Other closed social networks or institutional.; E2a Non-HDI country
E3. Comparative Effectiveness (multiple active interventions, no control condition, including pharmacogenetic studies and other studies looking at treatment matching)
E4. Insufficient followup time (<6 weeks)
E5. No relevant outcomes
E6. Population; E6a Studies limited to perinatal women currently experiencing or being treated for a depressive episode; E6b Studies limited to women with psychotic or development disorders (e.g., schizophrenia, pervasive development disorder); E6c Other population exclusions, including fear of childbirth, women experiencing perinatal loss, women with a traumatic birth experience
E7. Intervention; E7a General parenting education without a mental health component (e.g., prenatal or infant care classes); E7b Targeting partner’s depression; E7c Not one of the specified interventions or not feasible/referable; E7d Other intervention exclusion; E7e Attachment/parenting with mental health component, not depression-specific
E8. Study Design: KQ1: Not an RCT or CCT KQ2: Not an RCT/CCT, large comparative observation study, or systematic review (Pharmacotherapy only)
E9. Study Quality; E9a High or differential attrition; E9b Other quality issue; E9c Cohort/Case-control studies of harms of antidepressants: Fewer than 10 cases among exposed or unexposed (or few than 10 with exposure among cases or controls)
E10. Non-English
E11. Unable to locate article
E12. Conference and/or presentation abstract

* Assigned at full-text phase

1 Anton R, David D. A randomized clinical trial of a new preventive rational emotive and behavioral therapeutical program of prepartum and postpartum emotional distress. Journal of Evidence-Based Psychotherapies. 2015;15(1):3–15. KQ1E2a, KQ2E2a.
2 Araujo WS, Romero WG, Zandonade E, . Effects of relaxation on depression levels in women with high-risk pregnancies: a randomised clinical trial. Rev Lat Am Enfermagem. 2016;24(0):e2806. PMID: 27627126. 10.1590/1518-8345.1249.2806 KQ1E2, KQ2E2.27627126
3 Armstrong KL, Fraser JA, Dadds MR, . Promoting secure attachment, maternal mood and child health in a vulnerable population: a randomized controlled trial. J Paediatr Child Health. 2000;36(6):555–62. KQ1E7e, KQ2E7e.11115031
4 Austin MP, Frilingos M, Lumley J, . Brief antenatal cognitive behaviour therapy group intervention for the prevention of postnatal depression and anxiety: a randomised controlled trial. Journal of affective disorders. 2008;105(1–3):35–44. PMID: 17490753. 10.1016/j.jad.2007.04.001 KQ1E9, KQ2E9.17490753
5 Ayers S, Fitzgerald G, Thompson S. Brief online self-help exercises for postnatal women to improve mood: A pilot study. Matern Child Health J. 2015;19(11):2375–83. PMID: 26084670. 10.1007/s10995-015-1755-5 KQ1E4, KQ2E4.26084670
6 Backonja U, Robledo CA, Wallace ME, . Reproductive Health Knowledge among African American Women Enrolled in a Clinic-Based Randomized Controlled Trial to Reduce Psychosocial and Behavioral Risk: Project DC-HOPE. Womens Health Issues. 2016;26(4):442–51. PMID: 27094910. 10.1016/j.whi.2016.03.005 KQ1E5, KQ2E5.27094910
7 Baek E, Park H. [Effects of a Case Management Program on Self-efficacy, Depression and Anxiety in Pregnant Women with Gestational Diabetes Mellitus]. Korean Journal of Women Health Nursing. 2013;19(2):88–98. KQ1E10, KQ2E10.
8 Barnes J, Aistrop D, Allen E, . First steps: study protocol for a randomized controlled trial of the effectiveness of the Group Family Nurse Partnership (gFNP) program compared to routine care in improving outcomes for high-risk mothers and their children and preventing abuse. Trials [Electronic Resource]. 2013;14:285. PMID: 24011061. 10.1186/1745-6215-14-285 KQ1E5, KQ2E5.24011061
9 Barnes J, Senior R, MacPherson K. The utility of volunteer home-visiting support to prevent maternal depression in the first year of life. Child Care Health Dev. 2009;35(6):807–16. PMID: 19719770. 10.1111/j.1365-2214.2009.01007.x KQ1E9, KQ2E9.19719770
10 Barnet B, Liu J, DeVoe M, . Home visiting for adolescent mothers: effects on parenting, maternal life course, and primary care linkage. Ann Fam Med. 2007;5(3):224–32. PMID: 17548850. 10.1370/afm.629 KQ1E7e, KQ2E7e.17548850
11 Barrera AZ, Kelman AR, Munoz RF. Keywords to recruit Spanish- and English-speaking participants: evidence from an online postpartum depression randomized controlled trial. J Med Internet Res. 2014;16(1):e6. PMID: 24407163. 10.2196/jmir.2999 KQ1E1, KQ2E1.24407163
12 Barrera AZ, Wickham RE, Munoz RF. Online prevention of postpartum depression for Spanish- and English-speaking pregnant women: A pilot randomized controlled trial. Internet Interv. 2015;2(3):257–65. PMID: 26273567. 10.1016/j.invent.2015.06.002 KQ1E9, KQ2E9.26273567
13 Beeber LS, Holditch-Davis D, Belyea MJ, . In-home intervention for depressive symptoms with low-income mothers of infants and toddlers in the United States. Health Care Women Int. 2004;25(6):561–80. KQ1E6a, KQ2E6a.15354622
14 Beijers C, Verbeek T, Pampus M, ., editors. Cognitive behavioral therapy for treatment of antenatal anxiety and depressive symptoms: A randomized controlled trial. International Marce Society for Perinatal Mental Health Biennial Scientific Conference 2014; 2015; Swansea, UK. Springer-Verlag Wien. KQ1E12, KQ2E12.
15 Berkule S, Cates C, Dreyer B, . Reducing maternal depressive symptoms through promotion of parenting in pediatric primary care. Clinical pediatrics. 2014;53(5):460–9. 10.1177/0009922814528033 KQ1E9, KQ2E9.24707022
16 Bhati SR. The effect of the Sleep Support for Moms Intervention on postpartum sleep and depressive symptoms. a pilot Randomized Controlled Trial. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2015;76(2-B(E)):No Pagination Specified. KQ1E9, KQ2E9.
17 Bigelow A, Power M, MacLellan-Peters J, . Effect of mother/infant skin-to-skin contact on postpartum depressive symptoms and maternal physiological stress. J Obstet Gynecol Neonatal Nurs. 2012;41(3):369–82. PMID: 22537390. 10.1111/j.1552-6909.2012.01350.x KQ1E8, KQ2E8.22537390
18 Bittner A, Peukert J, Zimmermann C, . Early intervention in pregnant women with elevated anxiety and depressive symptoms: efficacy of a cognitive-behavioral group program. J Perinat Neonatal Nurs. 2014;28(3):185–95. PMID: 25062520. 10.1097/JPN.0000000000000027 KQ1E9, KQ2E9.25062520
19 Bjorklund U, Marsk A, Ohman SG. Does an information film about prenatal testing in early pregnancy affect women’s anxiety and worries? Journal of Psychosomatic Obstetrics & Gynecology. 2013;34(1):9–14. PMID: 2013-04829-003. 10.3109/0167482X.2012.756864 KQ1E1, KQ2E1.23394408
20 Bogaerts A, Devlieger R, Nuyts E, . Effects of lifestyle intervention in obese pregnant women on gestational weight gain and mental health: A randomized controlled trial. International Journal of Obesity. 2013;37(6):814–21. PMID: 2013-20773-003. 10.1038/ijo.2012.162 KQ1E1, KQ2E1.23032404
21 Bowen A, Baetz M, Schwartz L, . Antenatal group therapy improves worry and depression symptoms. Isr J Psychiatry Relat Sci. 2014;51(3):226–31. PMID: 25618288. KQ1E3, KQ2E3.25618288
22 Brugha T, Smith J, Bankart J, ., editors. Pregnancy and wellbeing study (PAWS). Taking action with midwives and perinatal primary care. Marce International Society International Biennial General Scientific Meeting - “Acting Together Around Childbirth” 2012; 2013 Oct 3–5; Paris, France. KQ1E5, KQ2E5.
23 Brugha TS, Smith J, Austin J, . Can community midwives prevent antenatal depression? An external pilot study to test the feasibility of a cluster randomized controlled universal prevention trial. Psychological Medicine. 2016;46(2):345–56. PMID: 26482473. 10.1017/S003329171500183X KQ1E6a, KQ2E6a.26482473
24 Buist A, Westley D, Hill C. Antenatal prevention of postnatal depression. Arch Womens Ment Health. 1999;1:167–73. PMID: None. KQ1E9, KQ2E9.
25 Bullock LF, Wells JE, Duff GB, . Telephone support for pregnant women: outcome in late pregnancy. N Z Med J. 1995;108(1012):476–8. KQ1E7e, KQ2E7e.8538974
26 Burger H, Bockting CL, Beijers C, . Pregnancy Outcomes After a Maternity Intervention for Stressful Emotions (PROMISES): A Randomised Controlled Trial. Adv Neurobiol. 2015;10:443–59. PMID: 25287553. 10.1007/978-1-4939-1372-5_21 KQ1E5, KQ2E5.25287553
27 Chabrol H, Teissedre F, Saint-Jean M, . Prevention and treatment of post-partum depression: a controlled randomized study on women at risk. Psychol Med. 2002;32(6):1039–47. PMID: 12214785. KQ1E4, KQ2E4.12214785
28 Chen CH, Tseng YF, Chou FH, . Effects of support group intervention in postnatally distressed women. A controlled study in Taiwan. J Psychosom Res. 2000;49(6):395–9. KQ1E4, KQ2E4.11182431
29 Cho HJ, Kwon JH, Lee JJ. Antenatal cognitive-behavioral therapy for prevention of postpartum depression: a pilot study. Yonsei Med J. 2008;49(4):553–62. PMID: 18729297. 10.3349/ymj.2008.49.4.553 KQ1E6a, KQ2E6a.18729297
30 Cote-Arsenault D, Schwartz K, Krowchuk H, . Evidence-based intervention with women pregnant after perinatal loss. MCN Am J Matern Child Nurs. 2014;39(3):177–86; quiz 87–8. PMID: 24472794. 10.1097/NMC.0000000000000024 KQ1E6c, KQ2E6c.24472794
31 Creedy D, Gamble J, Fenwick J, editors. Effect of a midwife-led counselling on mental health outcomes for women experiencing a traumatic childbirth: A RCT. Marce International Society International Biennial General Scientific Meeting - “Acting Together Around Childbirth” 2012; 2013 Oct 3–5; Paris, France. KQ1E12, KQ2E12.
32 Crockett K, Zlotnick C, Davis M, . A depression preventive intervention for rural low-income African–American pregnant women at risk for postpartum depression. Arch Womens Ment Health. 2008;11(5–6):319–25. PMID: 18982408. KQ1E9, KQ2E9.18982408
33 Currie M, Reay R, Thompson J, ., editors. Exercise and postnatal emotional wellbeing: A randomised controlled trial comparing two exercise and support programs. Marce International Society International Biennial General Scientific Meeting - “Acting Together Around Childbirth” 2012; 2013; Paris, France. KQ1E6a, KQ2E6a.
34 Di Blasio P, Miragoli S, Camisasca E, . Emotional Distress Following Childbirth: An Intervention to Buffer Depressive and PTSD Symptoms. Eur. 2015;11(2):214–32. PMID: 27247653. 10.5964/ejop.v11i2.779 KQ1E9, KQ2E9.27247653
35 Dimidjian S, Goodman S, Felder J, ., editors. Mindfulness based cognitive therapy for the prevention of perinatal depression: Initial findings. Marce International Society International Biennial General Scientific Meeting - “Acting Together Around Childbirth” 2012; 2013; Paris, France. Springer Wien. KQ1E12, KQ2E12.
36 Dimidjian S, Goodman SH, Felder JN, . An open trial of mindfulness-based cognitive therapy for the prevention of perinatal depressive relapse/recurrence. Arch Women Ment Health. 2015;18(1):85–94. PMID: 25298253. 10.1007/s00737-014-0468-x KQ1E8, KQ2E8.25298253
37 Dodge KA, Goodman WB, Murphy RA, . Implementation and randomized controlled trial evaluation of universal postnatal nurse home visiting. Am J Public Health. 2014;104: Suppl 1:S136–43. PMID: 24354833. 10.2105/AJPH.2013.301361 KQ1E1, KQ2E1.24354833
38 Doornbos B, van Goor SA, Dijck-Brouwer DA, . Supplementation of a low dose of DHA or DHA+AA does not prevent peripartum depressive symptoms in a small population based sample. Prog Neuropsychopharmacol Biol Psychiatry. 2009;33(1):49–52. KQ1E9, KQ2E9.18955102
39 Dowlati Y, Ravindran A, Segal Z, ., editors. Improved resilience against depressed mood in early postpartum after dietary supplement administration. 29th European College of Neuropsychopharmacology Congress, ECNP 2016; 2016 Sep 17–20, 2016; Austria. European neuropsychopharmacology. KQ1E12, KQ2E12.
40 Dowlati Y, Ravindran A, Segal Z, ., editors. Selective dietary supplementation in early postpartum is associated with high resilience against depressed mood. Proceedings of the National Academy of Sciences of the United States of America; 2017. KQ1E4, KQ2E4.
41 Dowlati Y, Ravindran A, Steiner M, . Novel strategy for preventing postpartum depression. Annals of nutrition & metabolism [serial on the Internet]. 2013;63. Available from: http://www.karger.com/Article/Pdf/354245. KQ1E1, KQ2E1.
42 Drozd F, Haga SM, Brendryen H, . An Internet-Based Intervention (Mamma Mia) for Postpartum Depression: Mapping the Development from Theory to Practice. JMIR Res Protoc. 2015;4(4):e120. PMID: 26476481. 10.2196/resprot.4858 KQ1E8, KQ2E8.26476481
43 Duncan LG, Cohn MA, Chao MT, . Benefits of preparing for childbirth with mindfulness training: a randomized controlled trial with active comparison. BMC Pregnancy & Childbirth. 2017;17(1):140. PMID: 28499376. 10.1186/s12884-017-1319-3 KQ1E7c, KQ2E7c.28499376
44 Effati-Daryani F, Mohammad-Alizadeh-Charandabi S, Mirghafourvand M, . Effect of Lavender Cream with or without Foot-bath on Anxiety, Stress and Depression in Pregnancy: a Randomized Placebo-Controlled Trial. J Caring Sci. 2015;4(1):63–73. PMID: 25821760. 10.5681/jcs.2015.007 KQ1E2a, KQ2E2a.25821760
45 Elliott SA, Leverton TJ, Sanjack M, . Promoting mental health after childbirth: a controlled trial of primary prevention of postnatal depression. Br J Clin Psychol. 2000;39 (Pt 3):223–41. PMID: 11033746. KQ1E9, KQ2E9.11033746
46 El-Mohandes AA, Kiely M, Joseph JG, . An intervention to improve postpartum outcomes in African-American mothers: a randomized controlled trial. Obstet Gynecol. 2008;112(3):611–20. KQ1E6a, KQ2E6a.18757660
47 Ericksen J, Milgrom J, Schembri C, ., editors. Towards parenthood. A public health intervention to prepare for the transition to parenthood. Marce International Society International Biennial General Scientific Meeting - “Acting Together Around Childbirth” 2012; 2013; Paris, France: Springer Wien. KQ1E12, KQ2E12.
48 Ertekin Pinar S, Duran Aksoy O, Daglar G, . Effect of stress management training on depression, stress and coping strategies in pregnant women: a randomised controlled trial. J Psychosom Obstet Gynaecol. 2017:1–8. PMID: 28472901. 10.1080/0167482x.2017.1321632 KQ1E2a, KQ2E2a.28472901
49 Ertekin PS, Duran AO, Datlar G, ., editors. Effects of coping with stress training on pregnant women’s depression, stress and coping with stress levels. 25th European Congress of Perinatal Medicine; 2016 June 15–18, 2016; the Netherlands. J Matern Fetal Neonatal Med. KQ1E12, KQ2E12.
50 Fausett M, Gill B, Esplin M, . Centering Pregnancy is associated with fewer early, but not overall, preterm deliveries. Am J Obstet Gynecol [serial on the Internet]. 210(1 suppl. 1): Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/099/CN-01062099/frame.html. KQ1E1, KQ2E1.
51 Feeley N, Zelkowitz P, Shrier I, . Follow-up of the Cues and Care trial: Mother and infant outcomes at 6 months. J Early Interv. 2012;34(2):65–81. PMID: 2012-22618-001. KQ1E6c, KQ2E6c.
52 Feinberg E, Stein R, Diaz-Linhart Y, . Adaptation of problem-solving treatment for prevention of depression among low-income, culturally diverse mothers. Fam Community Health. 2012;35(1):57–67. PMID: 22143488. 10.1097/FCH.0b013e3182385d48 KQ1E5, KQ2E5.22143488
53 Feinberg ME, Jones DE, Roettger ME, . Preventive Effects on Birth Outcomes: Buffering Impact of Maternal Stress, Depression, and Anxiety. Matern Child Health J. 2016;20(1):56–65. PMID: 26194453. 10.1007/s10995-015-1801-3 KQ1E5, KQ2E5.26194453
54 Felder JN, Epel E, Lewis JB, . Depressive symptoms and gestational length among pregnant adolescents: Cluster randomized control trial of CenteringPregnancy plus group prenatal care. J Consult Clin Psychol. 2017;85(6):574–84. PMID: 28287802. 10.1037/ccp0000191 KQ1E7d, KQ2E7d.28287802
55 Fenwick J, Gamble J, Creedy DK, . Study protocol for reducing childbirth fear: a midwife-led psycho-education intervention. BMC Pregnancy & Childbirth. 2013;13:190. PMID: 24139191. 10.1186/1471-2393-13-190 KQ1E6c, KQ2E6c.24139191
56 Fenwick J, Toohill J, Gamble J, . Effects of a midwife psycho-education intervention to reduce childbirth fear on women’s birth outcomes and postpartum psychological wellbeing. BMC Pregnancy & Childbirth. 2015;15:284. PMID: 26518597. 10.1186/s12884-015-0721-y KQ1E6c, KQ2E6c.26518597
57 Field T, Pickens J, Prodromidis M, . Targeting adolescent mothers with depressive symptoms for early intervention. Adolescence. 2000;35(138):381–414. PMID: 11019779. KQ1E6a, KQ2E6a.11019779
58 Fleming AS, Klein E, Corter C. The effects of a social support group on depression, maternal attitudes and behavior in new mothers. J Child Psychol Psychiatry. 1992;33(4):685–98. PMID: 1601943. KQ1E5, KQ2E5.1601943
59 Gamble J, Creedy D, Moyle W, . Effectiveness of a counseling intervention after a traumatic childbirth: a randomized controlled trial. Birth. 2005;32(1):11–9. PMID: 15725200. 10.1111/j.0730-7659.2005.00340.x KQ1E6c, KQ2E6c.15725200
60 Giallo R, Cooklin A, Dunning M, . The efficacy of an intervention for the management of postpartum fatigue. J Obstet Gynecol Neonatal Nurs. 2014;43(5):598–613. PMID: 25139257. 10.1111/1552-6909.12489 KQ1E7d, KQ2E7d.25139257
61 Ginsburg GS, Barlow A, Goklish N, . Postpartum Depression Prevention for Reservation-Based American Indians: Results from a Pilot Randomized Controlled Trial. Child Youth Care Forum. 2012;41(3):229–45. PMID: 22701296. 10.1007/s10566-011-9161-7 KQ1E3, KQ2E3.22701296
62 Goodman JH, Prager J, Goldstein R, . Perinatal Dyadic Psychotherapy for postpartum depression: a randomized controlled pilot trial. Arch Women Ment Health. 2015;18(3):493–506. PMID: 25522664. 10.1007/s00737-014-0483-y KQ1E3, KQ2E3.25522664
63 Gordon NP, Walton D, McAdam E, . Effects of providing hospital-based doulas in health maintenance organization hospitals. Obstet Gynecol. 1999;93(3):422–6. KQ1E2, KQ2E2.10074992
64 Gordon RE, Gordon KK. Social factors in prevention of postpartum emotional problems. Obstet Gynecol. 1960;15:433–8. PMID: 13851228. KQ1E5, KQ2E5.13851228
65 Griffiths K, Christensen H, Ellwood D, . Online cognitive behaviours therapy for the prevention of postnatal depression in at-risk mothers: a randomised controlled trial. Australian New Zealand Clinical Trials Registry; 2009. PMID: None. KQ1E12, KQ2E12.
66 Grote NK, Spieker SJ, Lohr MJ, . Impact of childhood trauma on the outcomes of a perinatal depression trial. Depression & Anxiety. 2012;29(7):563–73. PMID: 22447637. 10.1002/da.21929 KQ1E6a, KQ2E6a.22447637
67 Gunn J, Lumley J, Chondros P, . Does an early postnatal check-up improve maternal health: results from a randomised trial in Australian general practice. Br J Obstet Gynaecol. 1998;105(9):991–7. PMID: 9763051. KQ1E3, KQ2E3.9763051
68 Haga SM, Drozd F, Brendryen H, . Mamma mia: a feasibility study of a web-based intervention to reduce the risk of postpartum depression and enhance subjective well-being. JMIR Res Protoc. 2013;2(2):e29. PMID: 23939459. 10.2196/resprot.2659 KQ1E8, KQ2E8.23939459
69 Hagan R, Evans S, Pope S. Preventing postnatal depression in mothers of very preterm infants: a randomised controlled trial. Bjog. 2004;111(7):641–7. PMID: 15198752. KQ1E6c, KQ2E6c.15198752
70 Harmon TM, Hynan MT, Tyre TE. Improved obstetric outcomes using hypnotic analgesia and skill mastery combined with childbirth education. J Consult Clin Psychol. 1990;58(5):525–30. PMID: 2254498. KQ1E1, KQ2E1.2254498
71 Harris B, Oretti R, Lazarus J, . Randomised trial of thyroxine to prevent postnatal depression in thyroid-antibody-positive women. Br J Psychiatry. 2002;180:327–30. PMID: 11925355. KQ1E6c, KQ2E6c.11925355
72 Harris T, Brown G, Hamilton V, . The Newpin antenatal and postnatal project: a randomised controlled trial of an intervention for perinatal depression In: al. De, editor. 2006. PMID: None. KQ1E8, KQ2E8.
73 Harrison-Hohner J, Coste J, Donato V, . Prenatal calcium supplementation and postpartum depression: an ancillary study to a randomized trial of calcium for prevention of preeclampsia. Arch Women’s Menth Health. 2001;3:141–6. KQ1E9, KQ2E9.
74 Hatton DC, Harrison-Hohner J, Matarazzo J, . Missed antenatal depression among high risk women: a secondary analysis. Arch Womens Ment Health. 2007;10(3):121–3. PMID: 17431740. 10.1007/s00737-007-0180-1 KQ1E9b, KQ2E9.17431740
75 Heinicke C, Fineman N, Ruth G, . Relationship-based intervention with at-risk mothers: outcome in the first year of life. Infant Ment Health J. 1999;20(4):349–74. PMID: None. KQ1E7e, KQ2E7e.
76 Heller HM, van Straten A, de Groot CJ, . The (cost) effectiveness of an online intervention for pregnant women with affective symptoms: protocol of a randomised controlled trial. BMC Pregnancy & Childbirth. 2014;14:273. PMID: 25123230. 10.1186/1471-2393-14-273 KQ1E6a, KQ2E6a.25123230
77 Hesselink AE, van Poppel MN, van Eijsden M, . The effectiveness of a perinatal education programme on smoking, infant care, and psychosocial health for ethnic Turkish women. Midwifery. 2012;28(3):306–13. PMID: 21632158. 10.1016/j.midw.2011.04.005 KQ1E9, KQ2E9.21632158
78 Hiscock H, Cook F, Bayer J, ., editors. Can Early Infant Sleep and Crying Problems and Associated Postnatal Depression Be Prevented? A Randomized Controlled Trial. Pediatric Academic Societies Annual Meeting; 2013; Washington DC. KQ1E12, KQ2E12.
79 Ho SM, Heh SS, Jevitt CM, . Effectiveness of a discharge education program in reducing the severity of postpartum depression: a randomized controlled evaluation study. Patient Educ Couns. 2009;77(1):68–71. PMID: 19376677. 10.1016/j.pec.2009.01.009 KQ1E9, KQ2E9.19376677
80 Hodnett ED, Lowe NK, Hannah ME, . Effectiveness of nurses as providers of birth labor support in North American hospitals: a randomized controlled trial. JAMA. 2002;288(11):1373–81. KQ1E2, KQ2E2.12234231
81 Hoffman Y. The effects of a supportive intervention during and delivery on the postpartum psychological adaptation of first-time mothers: Case Western Reserve University; 1992. KQ1E2, KQ2E2.
82 Horowitz JA, Bell M, Trybulski J, . Promoting responsiveness between mothers with depressive symptoms and their infants. J Nurs Scholarsh. 2001;33(4):323–9. KQ1E7e, KQ2E7e.11775301
83 Huebner CE, Tyll L, Luallen J, . PrePare: a program of enhanced prenatal services within health-maintenance organization settings. Health Educ Res. 2001;16(1):71–80. PMID: 11252285. KQ1E7e, KQ2E7e.11252285
84 Ickovics JR, Kershaw TS, Westdahl C, . Group prenatal care and perinatal outcomes: a randomized controlled trial. Obstet Gynecol. 2007;110(2 Pt 1):330–9. KQ1E5, KQ2E5.17666608
85 Ickovics JR, Reed E, Magriples U, . Effects of group prenatal care on psychosocial risk in pregnancy: results from a randomised controlled trial. Psychol Health. 2011;26(2):235–50. PMID: 21318932. 10.1080/08870446.2011.531577 KQ1E7d, KQ2E7d.21318932
86 Jesse DE, Gaynes BN, Feldhousen EB, . Performance of a Culturally Tailored Cognitive-Behavioral Intervention Integrated in a Public Health Setting to Reduce Risk of Antepartum Depression: A Randomized Controlled Trial. J Midwifery Womens Health. 2015;60(5):578–92. PMID: 26261095. 10.1111/jmwh.12308 KQ1E9, KQ2E9.26261095
87 Johnston B, Huebner C, Anderson M, . Healthy steps in an integrated delivery system: child and parent outcomes at 30 months. Arch Pediatr Adolesc Med. 2006;160(8):793–800. PMID: 16894077. KQ1E7e, KQ2E7e.16894077
88 Johnston BD, Huebner CE, Tyll LT, . Expanding developmental and behavioral services for newborns in primary care; Effects on parental well-being, practice, and satisfaction. Am J Prev Med. 2004;26(4):356–66. PMID: 1511063. 10.1016/j.amepre.2003.12.018 KQ1E7e, KQ2E7e.15110063
89 Jones BA, Griffiths KM, Christensen H, . Online cognitive behaviour training for the prevention of postnatal depression in at-risk mothers: a randomised controlled trial protocol. BMC Psychiatry. 2013;13:265. PMID: 24131528. 10.1186/1471-244X-13-265 KQ1E5, KQ2E5.24131528
90 Judge M, Beck C, Durham H, . Pilot trial evaluating maternal docosahexaenoic acid consumption during pregnancy: Decreased postpartum depressive symptomatology. International Journal of Nursing Sciences. 2014;1(4):339–45. KQ1E9, KQ2E9.
91 Kamalifard M, Yavarikia P, Babapour Kheiroddin J, . The effect of peers support on postpartum depression: a single-blind randomized clinical trial. J Caring Sci. 2013;2(3):237–44. PMID: 25276732. 10.5681/jcs.2013.029 KQ1E2a, KQ2E2a.25276732
92 Kempler L, Sharpe L, Bartlett D. Sleep education during pregnancy for new mothers. BMC Pregnancy & Childbirth. 2012;12:155. PMID: 23244163. 10.1186/1471-2393-12-155 KQ1E5, KQ2E5.23244163
93 Kenyon S, Jolly K, Hemming K, . Effects of additional lay support for pregnant women with social risk factors on antenatal attendance and maternal psychological health: A randomised controlled trial (ELSIPS). Archives of Disease in Childhood: Fetal and Neonatal Edition [serial on the Internet]. 2014; 99. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/441/CN-01009441/frame.html KQ1E12, KQ2E12.
94 Kenyon S, Jolly K, Hemming K, . Evaluation of Lay Support in Pregnant women with Social risk (ELSIPS): a randomised controlled trial. BMC Pregnancy & Childbirth. 2012;12:11. PMID: 22375895. 10.1186/1471-2393-12-11 KQ1E5, KQ2E5.22375895
95 Kershaw TS, Magriples U, Westdahl C, . Pregnancy as a window of opportunity for HIV prevention: effects of an HIV intervention delivered within prenatal care. Am J Public Health. 2009;99(11):2079–86. PMID: 19762662. 10.2105/AJPH.2008.154476 KQ1E7d, KQ2E7d.19762662
96 Khazaie H, Ghadami MR, Knight DC, . Insomnia treatment in the third trimester of pregnancy reduces postpartum depression symptoms: a randomized clinical trial. Psychiatry Res. 2013;210(3):901–5. PMID: 23993464. 10.1016/j.psychres.2013.08.017 KQ1E2a, KQ2E2a.23993464
97 Kieffer E, Caldwell C, Welmerink D, . Effect of the healthy MOMs lifestyle intervention on reducing depressive symptoms among pregnant Latinas. Am J Community Psychol. 2013;51(1–2):76–89. PMID: 22638902. KQ1E1, KQ2E1.22638902
98 King E. The effectiveness of an internet-based stress management program in the prevention of postpartum stress, anxiety and depression for new mothers. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009;70:2560. KQ1E3, KQ2E3.
99 Kingston D, Austin MP, Hegadoren K, . Study protocol for a randomized, controlled, superiority trial comparing the clinical and cost-effectiveness of integrated online mental health assessment-referral-care in pregnancy to usual prenatal care on prenatal and postnatal mental health and infant health and development: the Integrated Maternal Psychosocial Assessment to Care Trial (IMPACT). Trials [Electronic Resource]. 2014;15:72. PMID: 24597683. 10.1186/1745-6215-15-72 KQ1E5, KQ2E5.24597683
100 Lara MA, Navarro C, Navarrete L. Outcome results of a psycho-educational intervention in pregnancy to prevent PPD: a randomized control trial. Journal of affective disorders. 2010;122(1–2):109–17. PMID: 19596446. 10.1016/j.jad.2009.06.024 KQ1E2a, KQ2E2a.19596446
101 Lavender T, Walkinshaw SA. Can midwives reduce postpartum psychological morbidity? A randomized trial. Birth. 1998;25(4):215–9. PMID: 9892887. KQ1E4, KQ2E4.9892887
102 Leung SS, Lee AM, Wong DF, . A brief group intervention using a cognitive-behavioural approach to reduce postnatal depressive symptoms: a randomised controlled trial. Hong Kong Med. 2016;22: Suppl 2:S4–8. PMID: 26908335. KQ1E9, KQ2E9.26908335
103 Lewis BA, Gjerdingen DK, Avery MD, . Examination of a telephone-based exercise intervention for the prevention of postpartum depression: design, methodology, and baseline data from The Healthy Mom study. Contemp Clin Trials. 2012;33(6):1150–8. PMID: 22890220. 10.1016/j.cct.2012.07.015 KQ1E3, KQ2E3.22890220
104 Lewis BA, Gjerdingen DK, Avery MD, . A randomized trial examining a physical activity intervention for the prevention of postpartum depression: The healthy mom trial. Mental Health and Physical Activity. 2014;7(1):42–9. PMID: 2014-12125-008. KQ1E3, KQ2E3.
105 Lipman EL, Boyle MH. Social support and education groups for single mothers: a randomized controlled trial of a community-based program. CMAJ. 2005;173(12):1451–6. KQ1E6c, KQ2E6c.16293780
106 Logsdon MC, Birkimer JC, Simpson T, . Postpartum depression and social support in adolescents. J Obstet Gynecol Neonatal Nurs. 2005;34(1):46–54. PMID: 15673645. 10.1177/0884217504272802 KQ1E9, KQ2E9.15673645
107 Lumley J, Small R, Brown S, . PRISM (Program of Resources, Information and Support for Mothers) Protocol for a community-randomised trial [ISRCTN03464021]. BMC Public Health. 2003;3:36. KQ1E7c, KQ2E7c.14629776
108 Lumley J, Watson L, Small R, . PRISM (Program of Resources, Information and Support for Mothers): a community-randomised trial to reduce depression and improve women’s physical health six months after birth [ISRCTN03464021]. BMC Public Health. 2006;6:37. PMID: 16483383. 10.1186/1471-2458-6-37 KQ1E7c, KQ2E7c.16483383
109 MacArthur C, Winter HR, Bick DE, . Redesigning postnatal care: a randomised controlled trial of protocol-based midwifery-led care focused on individual women’s physical and psychological health needs. Health Technol Assess. 2003;7(37):1–98. PMID: 14622490. KQ1E7d, KQ2E7d.14622490
110 Marks M, Siddle K, Warwick C. Can we prevent postnatal depression? A randomized controlled trial to assess the effect of continuity of midwifery care on rates of postnatal depression in high-risk women. J Matern Fetal Neonatal Med. 2003;13(2):119–27. PMID: 12735413. KQ1E9, KQ2E9.12735413
111 Matthey S, Kavanagh D, Howie P, . Prevention of postnatal distress or depression: an evaluation of an intervention at preparation for parenthood classes. Journal of affective disorders. 2004;79(1–3):113–26. PMID: 15023486. KQ1E9, KQ2E9.15023486
112 McFarlane E, Burrell L, Duggan A, . Outcomes of a Randomized Trial of a Cognitive Behavioral Enhancement to Address Maternal Distress in Home Visited Mothers. Matern Child Health J. 2016. PMID: 27535131. 10.1007/s10995-016-2125-7 KQ1E3, KQ2E3.27535131
113 McKee MD, Zayas LH, Fletcher J, . Results of an intervention to reduce perinatal depression among low-income minority women in community primary care. J Soc Serv Res. 2006;32:36–81. KQ1E6a, KQ2E6a.
114 Meeker C. A preventive intervention for postpartum depression in primiparous women (Unpublished doctoral dissertation). Lawrence, Kansas: University of Kansas; 1985. KQ1E9, KQ2E9.
115 Mendelson T, Leis JA, Perry DF, . Impact of a preventive intervention for perinatal depression on mood regulation, social support, and coping. Arch Womens Ment Health. 2013;16(3):211–8. KQ1E6a, KQ2E6a.23456540
116 Milani HS, Amiri P, Mohsey M, . Effect of Health Care as the “Home Visiting” on Postpartum Depression: A Controlled Clinical Trial.[Erratum appears in Int J Prev Med. 2017 May 25;8:38; PMID: 28584620]. Int J Prev Med. 2017;8:20. PMID: 28479962. 10.4103/2008-7802.204003 KQ1E2a, KQ2E2a.28479962
117 Miller B, Murray L, Beckmann M, . Dietary supplements for preventing postnatal depression (Protocol). Cohcrane Database of Systematic Reviews; 2011. PMID: None. KQ1E8, KQ2E8.
118 Miller L, Gur M, Shanok A, . Interpersonal psychotherapy with pregnant adolescents: two pilot studies. J Child Psychol Psychiatry. 2008;49(7):733–42. PMID: 18492043. 10.1111/j.1469-7610.2008.01890.x KQ1E2, KQ2E2.18492043
119 Mitchell J, Field T, Diego M, . Yoga reduces prenatal depression symptoms. Psychology (Savannah, Ga) [serial on the Internet]. 2012; 3(9a). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/522/CN-01038522/frame.html. KQ1E6a, KQ2E6a.
120 Mitchell JL. Yoga effects on prenatal depression. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2013;73(12-B(E)):No Pagination Specified. KQ1E6a, KQ2E6a.
121 Mohammad-Alizadeh-Charandabi S, Malakoti J, Sohrabi F, . The effect of telephone support on postpartum depression: a randomized controlled trial. J Caring Sci. 2013;2(2):147–55. PMID: 25276721. 10.5681/jcs.2013.018 KQ1E2a, KQ2E2a.25276721
122 Mokhber N, Namjoo M, Tara F, . Effect of supplementation with selenium on postpartum depression: a randomized double-blind placebo-controlled trial. J Matern Fetal Neonatal Med. 2011;24(1):104–8. PMID: 20528216. KQ1E2a, KQ2E2a.20528216
123 Mullany B, Barlow A, Neault N, . The Family Spirit trial for American Indian teen mothers and their children: CBPR rationale, design, methods and baseline characteristics. Prev Sci. 2012;13(5):504–18. PMID: 22932743. 10.1007/s11121-012-0277-2 KQ1E5, KQ2E5.22932743
124 Nalepka C, Coblentz M. Incidence of postpartum depression following antepartal intervention. Journal Perinatal Depression. 1995;4:29–37. PMID: None. KQ1E9, KQ2E9.
125 Newham JJ, Wittkowski A, Hurley J, . Effects of antenatal yoga on maternal anxiety and depression: a randomized controlled trial. Depression & Anxiety. 2014;31(8):631–40. PMID: 24788589. 10.1002/da.22268 KQ1E7d, KQ2E7d.24788589
126 Nezvalova-Henriksen K, Spigset O, Brandlistuen RE, . Effect of prenatal selective serotonin reuptake inhibitor (SSRI) exposure on birthweight and gestational age: a sibling-controlled cohort study. International journal of epidemiology. 2016. PMID: 27188860. 10.1093/ije/dyw049 KQ1E8, KQ2E5.27188860
127 Nikodem VC, Nolte AG, Wolman W, . Companionship by a lay labour supporter to modify the clinical birth environment: long-term effects on mother and child. Curationis. 1998;21(1):8–12. KQ1E2a, KQ2E2a.
128 Nugent J, Bartlett JD, Valim C. Effects of an infant-focused relationship-based hospital and home visiting intervention on reducing symptoms of postpartum maternal depression: A pilot study. Infants & Young Children. 2014;27(4):292–304. PMID: 2014-37315-003. KQ1E4, KQ2E4.
129 Nwebube C, Glover V, Stewart L. Prenatal listening to songs composed for pregnancy and symptoms of anxiety and depression: a pilot study. BMC Altern Med. 2017;17(1):256. PMID: 28482901. 10.1186/s12906-017-1759-3 KQ1E9a, KQ2E9a.28482901
130 Okano T, Hagata S, Hasegawa M, . Effectiveness of antenatal education about postnatal depression: a comparison of two groups of Japanese mothers. J Ment Health. 1998;7:191–8. KQ1E8, KQ2E8.
131 Oswalt KL, Biasini FJ, Wilson LL, . Outcomes of a massage intervention on teen mothers: a pilot study. Pediatr Nurs. 2009;35(5):284–9, 317. PMID: 19916344. KQ1E2, KQ2E2.19916344
132 Paoletti AM, Orru MM, Marotto MF, . Observational study on the efficacy of the supplementation with a preparation with several minerals and vitamins in improving mood and behaviour of healthy puerperal women. Gynecol Endocrinol. 2013;29(8):779–83. PMID: 23782001. 10.3109/09513590.2013.801447 KQ1E3, KQ2E3.23782001
133 Pessagno RA, Hunker D. Using short-term group psychotherapy as an evidence-based intervention for first-time mothers at risk for postpartum depression. Perspect Psychiatr Care. 2013;49(3):202–9. PMID: 23819670. 10.1111/j.1744-6163.2012.00350.x KQ1E8, KQ2E8.23819670
134 Previti G, Pawlby S, Chowdhury S, . Neurodevelopmental outcome for offspring of women treated for antenatal depression: a systematic review. Arch Women Ment Health. 2014;17(6):471–83. PMID: 25212663. 10.1007/s00737-014-0457-0 KQ1E8, KQ2E5.25212663
135 Ramezani S, Khosravi A, Motaghi Z, . The effect of cognitive-behavioural and solution-focused counselling on prevention of postpartum depression in nulliparous pregnant women. J Reprod Infant Psychol. 2017;35(2):172–82. PMID: 29517361. 10.1080/02646838.2016.1266470 KQ1E2a, KQ2E2a.29517361
136 Ravn IH, Smith L, Smeby NA, . Effects of early mother-infant intervention on outcomes in mothers and moderately and late preterm infants at age 1 year: a randomized controlled trial. Infant behav. 2012;35(1):36–47. PMID: 22024475. 10.1016/j.infbeh.2011.09.006 KQ1E6c, KQ2E6c.22024475
137 Rees BL. Effect of relaxation with guided imagery on anxiety, depression, and self-esteem in primiparas. J Holist Nurs. 1995;13(3):255–67. PMID: 7650352. KQ1E4, KQ2E4.7650352
138 Ride J, Rowe H, Wynter K, . Protocol for economic evaluation alongside a cluster-randomised controlled trial of a psychoeducational intervention for the primary prevention of postnatal mental health problems in first-time mothers. BMJ Open. 2014;4(10):e006226. PMID: 25280810. 10.1136/bmjopen-2014-006226 KQ1E5, KQ2E5.25280810
139 Robledo-Colonia AF, Sandoval-Restrepo N, Mosquera-Valderrama YF, . Aerobic exercise training during pregnancy reduces depressive symptoms in nulliparous women: a randomised trial. J Physiother. 2012;58(1):9–15. PMID: 22341377. 10.1016/S1836-9553(12)70067-X KQ1E2a, KQ2E2a.22341377
140 Rowe H, Wynter K, Lorgelly P, . A cluster randomised controlled trial of a brief couple-focused psychoeducational intervention to prevent common postnatal mental disorders among women: study protocol. BMJ Open. 2014;4(9):e006436. PMID: 25248497. 10.1136/bmjopen-2014-006436 KQ1E5, KQ2E5.25248497
141 Ryding EL, Wiren E, Johansson G, . Group counseling for mothers after emergency cesarean section: a randomized controlled trial of intervention. Birth. 2004;31(4):247–53. PMID: 15566336. 10.1111/j.0730-7659.2004.00316.x KQ1E6c, KQ2E6c.15566336
142 Saias T, Greacen T, Tubach F, . Supporting families in challenging contexts: the CAPEDP project. Glob Health Promot. 2013;20:(2 Suppl):66–70. PMID: 23678498. 10.1177/1757975913483335 KQ1E5, KQ2E5.23678498
143 Saisto T, Salmela-Aro K, Nurmi JE, . A randomized controlled trial of intervention in fear of childbirth. Obstet Gynecol. 2001;98(5 Pt 1):820–6. KQ1E6c, KQ2E6c.11704175
144 Sanaati F, Mohammad-Alizadeh Charandabi S, Farrokh Eslamlo H, . The effect of lifestyle-based education to women and their husbands on the anxiety and depression during pregnancy: a randomized controlled trial. J Matern Fetal Neonatal Med. 2016:1–7. PMID: 27186630. 10.1080/14767058.2016.1190821 KQ1E2a, KQ2E2a.27186630
145 Satyapriya M, Nagarathna R, Padmalatha V, . Effect of integrated yoga on anxiety, depression & well being in normal pregnancy. Complement Ther Clin Pract. 2013;19(4):230–6. PMID: 24199979. 10.1016/j.ctcp.2013.06.003 KQ1E2a, KQ2E2a.24199979
146 Sen D. A randomized controlled trial of midwife-led twin antenatal program [thesis]. Newcastle-upon-Tyne: University of Newcastle; 2006. KQ1E11, KQ2E11.
147 Serwint JR, Wilson MH, Duggan AK, . Do postpartum nursery visits by the primary care provider make a difference? Pediatrics. 1991;88(3):444–9. KQ1E7a, KQ2E7a.1881721
148 Shaw RJ, St John N, Lilo EA, . Prevention of traumatic stress in mothers with preterm infants: a randomized controlled trial. Pediatrics. 2013;132(4):e886–94. PMID: 23999956. 10.1542/peds.2013-1331 KQ1E6c, KQ2E6c.23999956
149 Shelton SL. Postpartum depressive symptoms: A study of influencing factors and an intervention for improvement. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2016;76(9-B(E)):No Pagination Specified. KQ1E9b, KQ2E9.
150 Shields N, Reid M. Impact of midwife-managed care in the postnatal period: an exploration of psychosocial outcomes J Reprod Infant Psychol. 1997;15:91–109. KQ1E7c, KQ2E7c.
151 Shorey S, Chan SW, Chong YS, . A randomized controlled trial of the effectiveness of a postnatal psychoeducation programme on self-efficacy, social support and postnatal depression among primiparas. J Adv Nurs. 2015;71(6):1260–73. PMID: 25496615. 10.1111/jan.12590 KQ1E9, KQ2E9.25496615
152 Shorey S, Chan WC, Chong YS, . A randomized controlled trial of the effectiveness of a postnatal psychoeducation programme on outcomes of primiparas: study protocol. J Adv Nurs. 2015;71(1):193–203. PMID: 24909836. 10.1111/jan.12461 KQ1E5, KQ2E5.24909836
153 Shorey S, Lau Y, Dennis CL, . A randomized-controlled trial to examine the effectiveness of the ‘Home-but not Alone’ mobile-health application educational programme on parental outcomes. J Adv Nurs. 2017;73(9):2103–17. PMID: 28276086. 10.1111/jan.13293 KQ1E4, KQ2E4.28276086
154 Shorey S, Ng YP, Danbjorg DB, . Effectiveness of the ‘Home-but not Alone’ mobile health application educational programme on parental outcomes: a randomized controlled trial, study protocol. J Adv Nurs. 2016;21:21. PMID: 27650320. 10.1111/jan.13151 KQ1E4, KQ2E4.27650320
155 Sikorski J, Wilson J, Clement S, . A randomised controlled trial comparing two schedules of antenatal visits: the antenatal care project. BMJ. 1996;312(7030):546–53. KQ1E1, KQ2E1.8595286
156 Silverstein M, Feinberg E, Cabral H, . Problem-solving education to prevent depression among low-income mothers of preterm infants: a randomized controlled pilot trial. Arch Womens Ment Health. 2011;14(4):317–24. PMID: 21667323. KQ1E6c, KQ2E6c.21667323
157 Simavli S, Kaygusuz I, Gumus I, . Effect of music therapy during vaginal delivery on postpartum pain relief and mental health. Journal of affective disorders. 2014;156:194–9. PMID: 24411681. 10.1016/j.jad.2013.12.027 KQ1E4, KQ2E4.24411681
158 Slykerman RF, Hood F, Wickens K, . Effect of Lactobacillus rhamnosus HN001 in Pregnancy on Postpartum Symptoms of Depression and Anxiety: A Randomised Double-blind Placebo-controlled Trial. EBioMedicine. 2017;24:159–65. PMID: 28943228. 10.1016/j.ebiom.2017.09.013 KQ1E1, KQ2E1.28943228
159 Small R, Lumley J, Toomey L. Midwife-led debriefing after operative birth: four to six year follow-up of a randomised trial [ISRCTN24648614]. BMC Med. 2006;4:3. KQ1E6c, KQ2E6c.16509986
160 Small R, Watson L, Gunn J, . Improving population-level maternal health: a hard nut to crack? Long term findings and reflections on a 16-community randomised trial in Australia to improve maternal emotional and physical health after birth [ISRCTN03464021]. PLoS ONE. 2014;9(2):e88457. PMID: 24586327. 10.1371/journal.pone.0088457 KQ1E7c, KQ2E7c.24586327
161 Snaith VJ, Hewison J, Steen IN, . Antenatal telephone support intervention with and without uterine artery Doppler screening for low risk nulliparous women: a randomised controlled trial. BMC Pregnancy Childbirth. 2014;14:121. PMID: 24685072. 10.1186/1471-2393-14-121 KQ1E1, KQ2E1.24685072
162 Steiner M, Fairman M, Jansen E. Can postpartum depression be prevented. Arch Womens Ment Health. 2003;6:(Suppl 2):106. PMID: None. KQ1E1, KQ2E1.
163 Sujan AC, Rickert ME, Öberg A, . Associations of maternal antidepressant use during the first trimester of pregnancy with preterm birth, small for gestational age, autism spectrum disorder, and attention-deficit/hyperactivity disorder in offspring. JAMA. 2017;317(15):1553–62. PMID: 28418479. 10.1001/jama.2017.3413 KQ1E8, KQ2E7d.28418479
164 Surkan PJ, Gottlieb BR, McCormick MC, . Impact of a health promotion intervention on maternal depressive symptoms at 15 months postpartum. Maternal & Child Health Journal. 2012;16(1):139–48. PMID: 21153759. 10.1007/s10995-010-0729-x KQ1E7d, KQ2E7d.21153759
165 Tahmasian M, Khazaie H, Ghadami M, . Insomnia treatment in the third trimester of pregnancy prevents postpartum depression: A randomized clinical trial. Sleep medicine. 2013;14:e39. KQ1E2a, KQ2E2a.
166 Takehara K, Okamura M, Sugiura N, . Study protocol for a randomised controlled trial to test the effectiveness of providing information on childbirth and postnatal period to partners of pregnant women. BMJ Open. 2016;6(7):e011919. PMID: 27466241. 10.1136/bmjopen-2016-011919 KQ1E5, KQ2E5.27466241
167 Tam W, Lee D, Chiu H, . A randomised controlled trial of educational counselling on the management of women who have suffered suboptimal outcomes in pregnancy. BJOG. 2003;110(9):853–9. PMID: 14511969. KQ1E6c, KQ2E6c.14511969
168 Tandon S, Leis J, Mendelson T, ., editors. Preventing perinatal depression among low-income women enrolled in home visitation. Marce International Society International Biennial General Scientific Meeting - “Acting Together Around Childbirth” 2012; 2013 Oct 3–5; Paris, France. KQ1E12, KQ2E12.
169 Taniguchi C, Sato C. Home-based walking during pregnancy affects mood and birth outcomes among sedentary women: A randomized controlled trial. Int J Nurs Pract. 2016;22(5):420–6. PMID: 27272937. 10.1111/ijn.12453 KQ1E7d, KQ2E7d.27272937
170 Toohill J, Fenwick J, Gamble J, . A randomized controlled trial of a psycho-education intervention by midwives in reducing childbirth fear in pregnant women. Birth. 2014;41(4):384–94. PMID: 25303111. 10.1111/birt.12136 KQ1E1, KQ2E1.25303111
171 Vaz JDS, Farias DR, Adegboye ARA, . Omega-3 supplementation from pregnancy to postpartum to prevent depressive symptoms: a randomized placebo-controlled trial. BMC Pregnancy Childbirth. 2017;17(1):180. PMID: 28599630. 10.1186/s12884-017-1365-x KQ1E2a, KQ2E2a.28599630
172 Waldenstrom U, Brown S, McLachlan H, . Does team midwife care increase satisfaction with antenatal, intrapartum, and postpartum care? A randomized controlled trial. Birth. 2000;27(3):156–67. PMID: 11251496. KQ1E1, KQ2E1.11251496
173 Walkup JT, Barlow A, Mullany BC, . Randomized controlled trial of a paraprofessional-delivered in-home intervention for young reservation-based American Indian mothers. J Am Acad Child Adolesc Psychiatry. 2009;48(6):591–601. PMID: 19454915. 10.1097/CHI.0b013e3181a0ab86 KQ1E9, KQ2E9.19454915
174 Webster J, Linnane J, Roberts J, . Identify, Educate and Alert (IDEA) trial: an intervention to reduce postnatal depression. BJOG. 2003;110(9):842–6. PMID: 14511967. KQ1E9, KQ2E9.14511967
175 Weidner K, Bittner A, Junge-Hoffmeister J, . A psychosomatic intervention in pregnant in-patient women with prenatal somatic risks. J Psychosom Obstet Gynaecol. 2010;31(3):188–98. PMID: 20586556. 10.3109/0167482X.2010.497233 KQ1E2, KQ2E2.20586556
176 Wheatley S, Brugha T. ‘Just because I like it doesn’t mean it has to work’: personal experiences of an antenatal psychosocial intervention designed to prevent postnatal depression. Int J Ment Health Promot. 1999;1:26–31. KQ1E8, KQ2E8.
177 Wisner KL, Peindl KS, Perala ML. Sertraline prevents postpartum depression. Arch Womens Ment Health. 2003;6:(Suppl 2):100. KQ1E12, KQ2E12.
178 Wolman WL, Chalmers B, Hofmeyr GJ, . Postpartum depression and companionship in the clinical birth environment: a randomized, controlled study. Am J Obstet Gynecol. 1993;168(5):1388–93. PMID: 8498417. KQ1E2, KQ2E2.8498417
179 Young S, Gryder L, Cross C, ., editors. Placentophagy’s effects on postpartum maternal affect, health, and recovery. 86th annual meeting of the American Association of Physical Anthropologists; 2017; United States. American journal of physical anthropology. KQ1E12, KQ2E12.
180 Young SM, Gryder LK, Cross C, . Placentophagy’s effects on mood, bonding, and fatigue: A pilot trial, part 2. Women Birth. 2017. PMID: 29174273. 10.1016/j.wombi.2017.11.004 KQ1E4, KQ2E4.29174273
181 Zayas LH, McKee MD, Jankowski KR. Adapting psychosocial intervention research to urban primary care environments: a case example. Ann Fam Med. 2004;2(5):504–8. PMID: 15506589. KQ1E6a, KQ2E6a.15506589
182 Zhang H. A mindfulness-based intervention for urban, low-income, pregnant African American women. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2014;75(6-B(E)):No Pagination Specified. KQ1E9, KQ2E9.
183 Zhang H, Emory EK. A mindfulness-based intervention for pregnant African-American women. Mindfulness. 2015;6(3):663–74. KQ1E9, KQ2E9.