# Appendix C Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

- Brugha TS, Morrell CJ, Slade P, . Universal prevention of depression in women postnatally: cluster randomized trial evidence in primary care. Psychol Med. 2011;41(4):739–48. PMID: 20716383. 10.1017/S0033291710001467 20716383
  - Morrell CJ, Slade P, Warner R, . Clinical effectiveness of health visitor training in psychologically informed approaches for depression in postnatal women: pragmatic cluster randomised trial in primary care. BMJ. 2009;338:a3045. PMID: 19147636. 10.1136/bmj.a3045 19147636
- Brugha TS, Wheatley S, Taub NA, . Pragmatic randomized trial of antenatal intervention to prevent post-natal depression by reducing psychosocial risk factors. Psychol Med. 2000;30(6):1273–81. PMID: 11097068.11097068
  - Wheatley S, Culverwell A, Brugha T, . Preparing for parenthood: background and development of a risk modifying intervention to prevent postnatal depression. Arch Womens Ment Health. 2000;3:81–90.
- Cooper PJ, De Pascalis L, Woolgar M, . Attempting to prevent postnatal depression by targeting the mother-infant relationship: a randomised controlled trial. Prim Health Care Res Dev. 2015;16(4):383–97. PMID: 25381790. 10.1017/S1463423614000401 25381790
- Davis K, Goodman SH, Leiferman J, . A randomized controlled trial of yoga for pregnant women with symptoms of depression and anxiety. Complement Ther Clin Pract. 2015;21(3):166–72. PMID: 26256135. 10.1016/j.ctcp.2015.06.005 26256135
- Dennis C, Hodnett E, Kenton L, . Effect of peer support on prevention of postnatal depression among high risk women: multisite randomised controlled trial. BMJ. 2009;338:a3064. PMID: 19147637.19147637
  - Dennis CL. The process of developing and implementing a telephone-based peer support program for postpartum depression: evidence from two randomized controlled trials. Trials. 2014;15:131. PMID: 24742217. 10.1186/1745-6215-15-131 24742217
- Dennis CL. The effect of peer support on postpartum depression: a pilot randomized controlled trial. Can J Psychiatry. 2003;48(2):115–24. PMID: 12655910. 10.1177/070674370304800209 12655910
- Di Blasio P, Camisasca E, Caravita SC, . The Effects of Expressive Writing on Postpartum Depression and Posttraumatic Stress Symptoms. Psychol Rep. 2015;117(3):856–82. PMID: 26595300. 10.2466/02.13.PR0.117c29z3 26595300
- Dimidjian S, Goodman SH, Felder JN, . Staying well during pregnancy and the postpartum: A pilot randomized trial of mindfulness-based cognitive therapy for the prevention of depressive relapse/recurrence. J Consult Clin Psychol. 2016;84(2):134–45. PMID: 26654212. 10.1037/ccp0000068 26654212
- Dugravier R, Tubach F, Saias T, . Impact of a manualized multifocal perinatal home-visiting program using psychologists on postnatal depression: the CAPEDP randomized controlled trial. PLoS One. 2013;8(8):e72216. PMID: 23977257. 10.1371/journal.pone.0072216 23977257
- Feinberg M, Kan M. Establishing family foundations: intervention effects on coparenting, parent/infant well-being, and parent-child relations. J Fam Psychol. 2008;22(2):253–63. PMID: 18410212. 10.1037/0893-3200.22.2.253 18410212
- Fisher J, Rowe H, Wynter K, . Gender-informed, psychoeducational programme for couples to prevent postnatal common mental disorders among primiparous women: cluster randomised controlled trial. BMJ Open. 2016;6(3):e009396. PMID: 26951210. 10.1136/bmjopen-2015-009396 26951210
- Fontein-Kuipers YJ, Ausems M, de Vries R, . The effect of Wazzup Mama?! An antenatal intervention to prevent or reduce maternal distress in pregnancy. Arch Women Ment Health. 2016;19(5):779–88. PMID: 26965708. 10.1007/s00737-016-0614-8 26965708
- Gorman L. Prevention of postpartum difficulties in a high risk sample [dissertation]: University of Iowa; 1997.
- Hayes B, Muller R, Bradley B. Perinatal depression: a randomized controlled trial of an antenatal education intervention for primiparas. Birth. 2001;28(1):28–35. PMID: 11264626.11264626
- Heh SS, Fu YY. Effectiveness of informational support in reducing the severity of postnatal depression in Taiwan. J Adv Nurs. 2003;42(1):30–6. PMID: 12641809.12641809
- Hiscock H, Cook F, Bayer J, . Preventing early infant sleep and crying problems and postnatal depression: a randomized trial. Pediatrics. 2014;133(2):e346–54. PMID: 24394682. 10.1542/peds.2013-1886 24394682
  - Cook F, Bayer J, Le HN, . Baby Business: a randomised controlled trial of a universal parenting program that aims to prevent early infant sleep and cry problems and associated parental depression. BMC Pediatr. 2012;12:13. PMID: 22309617. 10.1186/1471-2431-12-13 22309617
- Hiscock H, Wake M. Randomised controlled trial of behavioural infant sleep intervention to improve infant sleep and maternal mood. BMJ. 2002;324(7345):1062–5. PMID: 11991909.11991909
- Howell E, Balbierz A, Wang J, . Reducing postpartum depressive symptoms among black and latina mothers: a randomized controlled trial. Obstet Gynecol. 2012;119(5):942–9. PMID: 22488220.22488220
- Howell EA, Bodnar-Deren S, Balbierz A, . An intervention to reduce postpartum depressive symptoms: a randomized controlled trial. Arch Womens Ment Health. 2014;17(1):57–63. PMID: 24019052. 10.1007/s00737-013-0381-8 24019052
- Kenyon S, Jolly K, Hemming K, . Lay support for pregnant women with social risk: a randomised controlled trial. BMJ Open. 2016;6(3):e009203. PMID: 26936901. 10.1136/bmjopen-2015-009203 26936901
- Kozinszky Z, Dudas R, Devosa I, . Can a brief antepartum preventive group intervention help reduce postpartum depressive symptomatology? Psychother Psychosom. 2012;81(2):98–107. PMID: 22261988.22261988
- Le HN, Perry DF, Stuart EA. Randomized controlled trial of a preventive intervention for perinatal depression in high-risk Latinas. J Consult Clin Psychol. 2011;79(2):135–41. PMID: 21319897. 10.1037/a0022492 21319897
  - Le HN, Perry DF, Genovez M, . In their own voices: Latinas’ experiences with a randomized controlled trial. Qual Health Res. 2013;23(6):834–46. PMID: 23539092. 10.1177/1049732313482591 23539092
- Leung SS, Lam TH. Group antenatal intervention to reduce perinatal stress and depressive symptoms related to intergenerational conflicts: a randomized controlled trial. International Journal of Nursing Studies. 2012;49(11):1391–402. PMID: 22818396. 10.1016/j.ijnurstu.2012.06.014 22818396
- Llorente AM, Jensen CL, Voigt RG, . Effect of maternal docosahexaenoic acid supplementation on postpartum depression and information processing. Am J Obstet Gynecol. 2003;188(5):1348–53. PMID: 12748510.12748510
- MacArthur C, Winter HR, Bick DE, . Effects of redesigned community postnatal care on womens’ health 4 months after birth: a cluster randomised controlled trial. Lancet. 2002;359(9304):378–85. PMID: 11844507.11844507
- Maimburg RD, Vaeth M. Postpartum depression among first-time mothers - results from a parallel randomised trial. Sex Reprod Healthc. 2015;6(2):95–100. PMID: 25998877. 10.1016/j.srhc.2015.01.003 25998877
- Milgrom J, Schembri C, Ericksen J, . Towards parenthood: an antenatal intervention to reduce depression, anxiety and parenting difficulties. Journal of affective disorders. 2011;130(3):385–94. PMID: 21112641. 10.1016/j.jad.2010.10.045 21112641
- Morrell CJ, Spiby H, Stewart P, . Costs and effectiveness of community postnatal support workers: randomised controlled trial. BMJ. 2000;321(7261):593–8. PMID: 10977833.10977833
  - Morrell CJ, Spiby H, Stewart P, . Costs and benefits of community postnatal support workers: a randomised controlled trial. Health Technol Assess. 2000;4(6):1–100. PMID: 10858637.10858637
- Mozurkewich EL, Clinton CM, Chilimigras JL, . The Mothers, Omega-3, and Mental Health Study: a double-blind, randomized controlled trial. Am J Obstet Gynecol. 2013;208(4):313 e1–9. PMID: 23531328. 10.1016/j.ajog.2013.01.038 23531328
  - Williams JA, Romero VC, Clinton CM, . Vitamin D levels and perinatal depressive symptoms in women at risk: a secondary analysis of the mothers, omega-3, and mental health study. BMC Pregnancy Childbirth. 2016;16(1):203. PMID: 27485050. 10.1186/s12884-016-0988-7 27485050
- Munoz R, Le H, Ippen C, . Prevention of Postpartum Depression in Low-Income Women: Development of the Mamás y Bebés/Mothers and Babies Course. Cognitive and Behavioral Practice. 2007;14:70–83.
- Norman E, Sherburn M, Osborne RH, . An exercise and education program improves well-being of new mothers: a randomized controlled trial. Phys Ther. 2010;90(3):348–55. PMID: 20056720. 10.2522/ptj.20090139 20056720
- Ortiz Collado MA, Saez M, Favrod J, . Antenatal psychosomatic programming to reduce postpartum depression risk and improve childbirth outcomes: a randomized controlled trial in Spain and France. BMC Pregnancy Childbirth. 2014;14:22. PMID: 24422605. 10.1186/1471-2393-14-22 24422605
- Perales M, Refoyo I, Coteron J, . Exercise during pregnancy attenuates prenatal depression: a randomized controlled trial. Eval Health Prof. 2015;38(1):59–72. PMID: 24872442. 10.1177/0163278714533566 24872442
- Phipps MG, Raker CA, Ware CF, . Randomized controlled trial to prevent postpartum depression in adolescent mothers. Am J Obstet Gynecol. 2013;208(3):192 e1–6. PMID: 23313720. 10.1016/j.ajog.2012.12.036 23313720
  - Venkatesh KK, Phipps MG, Triche EW, . The relationship between parental stress and postpartum depression among adolescent mothers enrolled in a randomized controlled prevention trial. Matern Child Health J. 2014;18(6):1532–9. PMID: 24281848. 10.1007/s10995-013-1394-7 24281848
- Priest S, Henderson J, Evans S, . Stress debriefing after childbirth: a randomised controlled trial. Med J Aust. 2003;178(11):542–5. PMID: 12765500.12765500
  - Reid M, Glazener C, Murray G, . A two-centred pragmatic randomised controlled trial of two interventions of postnatal support. BJOG. 2002;109(10):1164–70. PMID: 12387471.12387471
- Reid M, Glazener C, Connery L, . Two interventions for postnatal support. Br J Midwifery. 2003;11(5):294–8.
- Small R, Lumley J, Donohue L, . Randomised controlled trial of midwife led debriefing to reduce maternal depression after operative childbirth. BMJ. 2000;321(7268):1043–7. PMID: 11053173.11053173
- Songoygard K, Stafne S, Evensen K, . Does exercise during pregnancy prevent postnatal depression? A randomized controlled trial. Acta Obstet Gynecol Scand. 2012;91(1):62–7. PMID: 21880023.21880023
  - Stamp GE, Williams AS, Crowther CA. Evaluation of antenatal and postnatal support to overcome postnatal depression: a randomized, controlled trial. Birth. 1995;22(3):138–43. PMID: 7575861.7575861
- Stamp GE. Postnatal depression: prevalence, prediction, and preventive intervention by randomised trial. Wollongong: University of Wollongong; 1997.
- Tandon SD, Leis JA, Mendelson T, . Six-month outcomes from a randomized controlled trial to prevent perinatal depression in low-income home visiting clients. Matern Child Health J. 2014;18(4):873–81. PMID: 23793487. 10.1007/s10995-013-1313-y 23793487
- Tandon SD, Perry DF, Mendelson T, . Preventing perinatal depression in low-income home visiting clients: a randomized controlled trial. J Consult Clin Psychol. 2011;79(5):707–12. PMID: 21806298. 10.1037/a0024895 21806298
- Werner EA, Gustafsson HC, Lee S, . PREPP: postpartum depression prevention through the mother-infant dyad. Arch Women Ment Health. 2016;19(2):229–42. PMID: 26231973. 10.1007/s00737-015-0549-5 26231973
  - Wiggins M, Oakley A, Roberts I, . The Social Support and Family Health Study: a randomised controlled trial and economic evaluation of two alternative forms of postnatal support for mothers living in disadvantaged inner-city areas. Health Technol Assess. 2004;8(32):iii, ix–x, 1–120. PMID: 15298823.15298823
- Wiggins M, Oakley A, Roberts I, . Postnatal support for mothers living in disadvantaged inner city areas: a randomised controlled trial. J Epidemiol Community Health. 2005;59(4):288–95. PMID: 15767382. 10.1136/jech.2004.021808 15767382
- Wisner KL, Perel JM, Peindl KS, . Prevention of recurrent postpartum depression: a randomized clinical trial. J Clin Psychiatry. 2001;62(2):82–6. PMID: 11247106.11247106
- Wisner KL, Perel JM, Peindl KS, . Prevention of postpartum depression: a pilot randomized clinical trial. Am J Psychiatry. 2004;161(7):1290–2. PMID: 15229064. 10.1176/appi.ajp.161.7.1290 15229064
- Woolhouse H, Mercuri K, Judd F, . Antenatal mindfulness intervention to reduce depression, anxiety and stress: a pilot randomised controlled trial of the MindBabyBody program in an Australian tertiary maternity hospital. BMC Pregnancy & Childbirth. 2014;14:369. PMID: 25343848. 10.1186/s12884-014-0369-z 25343848
- Zlotnick C, Capezza NM, Parker D. An interpersonally based intervention for low-income pregnant women with intimate partner violence: a pilot study. Arch Womens Ment Health. 2011;14(1):55–65. PMID: 21153559. 10.1007/s00737-010-0195-x 21153559
- Zlotnick C, Johnson SL, Miller IW, . Postpartum depression in women receiving public assistance: pilot study of an interpersonal-therapy-oriented group intervention. Am J Psychiatry. 2001;158(4):638–40. PMID: 11282702. 10.1176/appi.ajp.158.4.638 11282702
- Zlotnick C, Miller I, Pearlstein T, . A preventive intervention for pregnant women on public assistance at risk for postpartum depression. Am J Psychiatry. 2006;163(8):1443–5. PMID: 16877662.16877662
  - Kao JC, Johnson JE, Todorova R, . The Positive Effect of a Group Intervention to Reduce Postpartum Depression on Breastfeeding Outcomes in Low-Income Women. Int J Group Psychother. 2015;65(3):445–58. PMID: 26076207. 10.1521/ijgp.2015.65.3.445 26076207
- Zlotnick C, Tzilos G, Miller I, . Randomized controlled trial to prevent postpartum depression in mothers on public assistance. Journal of affective disorders. 2016;189:263–8. PMID: 26454186. 10.1016/j.jad.2015.09.059 26454186

Ancillary Articles to the Mother & Babies Intervention:

- Le HN, Perry DF, Mendelson T, . Preventing Perinatal Depression in High Risk Women: Moving the Mothers and Babies Course from Clinical Trials to Community Implementation. Matern Child Health J. 2015;19(10):2102–10. PMID: 25673369. 10.1007/s10995-015-1729-7 25673369
- Mendelson T, Leis JA, Perry DF, . Impact of a preventive intervention for perinatal depression on mood regulation, social support, and coping. Arch Women Ment Health. 2013;16(3):211–8. PMID: 23456540. 10.1007/s00737-013-0332-4 23456540