# Appendix B Antidepressant and FDA Pregnancy Categories

Category | Drug Class | Generic Names (Brand Name), Pregnancy Class if available, narrative conclusion if class is not available
First-Generation | Tricyclic Antidepressants (TCAs) | - Amitriptyline, C; - Amoxapine. C; - Clomipramine, C; - Desipramine (Norpramin), NR. Safe use of desipramine hydrochloride during pregnancy and lactation has not been established; - Doxepin (Sinequan), NR. No evidence of harm in animal studies, but safety in humans has not been established; - Imipramine (Tofranil), NR. There have been clinical reports of congenital malformations associated with the use of the drug. Although a causal relationship between these effects and the drug could not be established, the possibility of fetal risk from the maternal ingestion of Imipramine Hydrochloride cannot be excluded.; - Maprotiline, NR. No evidence of impaired fertility or harm to the fetus due to maprotiline in animal studies. There are, however, no adequate and well controlled studies in pregnant women.; - Nortriptyline (Pamelor), NR. Safe use of nortriptyline hydrochloride during pregnancy and lactation has not been established; - Protriptyline (Vivactil), NR. Safe use in pregnancy and lactation has not been established; no apparent adverse effects on reproduction in animal studies; - Trimipramine (Surmontil), C
First-Generation | Monoamine Oxidase Inhibitors (MAOIs) | - Isocarboxazid (Marplan), C; - Phenelzine (Nardil), The safe use of this drug during pregnancy or lactation has not been established; - Selegiline (Emsam [transdermal patch]), C; - Tranylcypromine (Parnate), Animal reproductive studies show that tranylcypromine sulfate passes through the placental barrier into the fetus of the rat, and into the milk of the lactating dog, but safety in humans has not been established.
Second-Generation | Selective Serotonin Re-Uptake Inhibitors (SSRIs)* | - Citalopram (Celexa), C; - Escitalopram (Lexapro), C; - Fluoxetine (Prozac), C; - Fluvoxamine, C; - Paroxetine* (Paxil, Pexeva), D; - Sertraline* (Zoloft), C
Second-Generation | Selective Serotonin/Norepin ephrine Re-uptake Inhibitors (SNRIs) | - Desvenlafaxine (Pristiq), C; - Duloxetine (Cymbalta), C; - Venlafaxine (Effexor), C
Second-Generation | Dopamine Re-Uptake Inhibitors (DRIs) | Bupropion (Wellbutrin), C
Second-Generation | 5-HT_2A_ Receptor Antagonists | Nefazodone, C
Second-Generation | Serotonin Re-Uptake Inhibitors (SRIs) | Trazadone, C
Second-Generation | Tetracyclic Antidepressants (TeCAs) | Mirtazapine, C

Abbreviations: FDA = Food and Drug Administration; NR = not reported