# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

Databases searched:

Cochrane Central Register of Controlled Trials (CENTRAL)

MEDLINE

PsycInfo

PubMed

Key:

- / = MeSH subject heading
- $ = truncation
- * = truncation ab = word in abstract
- adj# = adjacent within × number of words
- cc = classification code
- hw = subject heading word
- id = key phrase identifier
- kw = keyword
- md = methodology
- pt = publication type
- ti = word in title

## Cochrane Central Register of Controlled Trials (Wiley)

Issue 10 of 12, February 2018

Search Name: Postpartum depression prevention_KQ search_FINAL

#1 pregnan*:ti,ab,kw 32053
#2 prenatal:ti,ab,kw 4181
#3 pre natal:ti,ab,kw 69
#4 perinatal:ti,ab,kw 3132
#5 peri natal:ti,ab,kw 10
#6 antenatal:ti,ab,kw 2160
#7 ante natal:ti,ab,kw 26
#8 antepartum:ti,ab,kw 295
#9 ante partum:ti,ab,kw 19
#10 postnatal:ti,ab,kw 2354
#11 post natal:ti,ab,kw 185
#12 postpartum:ti,ab,kw 4489
#13 post partum:ti,ab,kw 753
#14 (new next mother*):ti,ab,kw 96
#15 puerperal:ti,ab,kw 869
#16 ^65-#15^ 36870
#17 depress*:ti,ab,kw 48301
#18 dysthym*:ti,ab,kw 647
#19 (anxiety or anxious):ti,ab,kw 26211
#20 blues:ti,ab,kw 65
#21 #17 or #18 or #19 or #20 63262
#22 prevent*:ti,ab,kw 95755
#23 (reduc* or decreas*):ti,ab,kw near/5 (risk or incidence* or symptom*):ti,ab,kw 45109
#24 (reduc* or decreas*):ti,ab,kw near/5 (depress* or unhapp* or melanchol* or despond* or despair or grief or malaise):ti,ab,kw 5054
#25 relaps*:ti,ab,kw 19197
#26 #22 or #23 or #24 or #25 144707
#27 #16 and #21 and #26 Publication Year from 2012 to 2016, in Trials 289

## Medline (Ovid)

Database: Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Ovid MEDLINE(R) Daily and Ovid MEDLINE(R) <1946 to Present>

------------------------------------------------------------

1. Pregnancy/ (834482)
2. Pregnant women/ (6519)
3. Prenatal care/ (24446)
4. Perinatal care/ (3772)
5. Postnatal care/ (4948)
6. Postpartum period/ (22822)
7. Peripartum period/ (688)
8. Maternal Health Services/ (12346)
9. Puerperal Disorders/ (11065)
10. pregnan$.ti,ab. (451852)
11. prenatal.ti,ab. (84508)
12. pre natal.ti,ab. (1009)
13. perinatal.ti,ab. (64187)
14. peri natal.ti,ab. (184)
15. antenatal.ti,ab. (29619)
16. ante natal.ti,ab. (481)
17. antepartum.ti,ab. (5220)
18. ante partum.ti,ab. (410)
19. postnatal.ti,ab. (99660)
20. post natal.ti,ab. (6724)
21. postpartum.ti,ab. (44733)
22. post partum.ti,ab. (10424)
23. new mother$.ti,ab. (1484)
24. puerperal.ti,ab. (5648)
25. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 (1071183)
26. Depression/ (102459)
27. Depressive Disorder/ (70504)
28. Depressive Disorder, Major/ (27158)
29. Dysthymic Disorder/ (1209)
30. Anxiety/ (69189)
31. depress$.ti,ab. (405699)
32. dysthym$.ti,ab. (3166)
33. (anxiety or anxious).ti,ab. (160007)
34. blues.ti,ab. (1688)
35. 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 (548196)
36. 25 and 35 (26972)
37. Depression, Postpartum/ (4887)
38. 36 or 37 (27731)
39. prevent$.ti,ab. (1243515)
40. ((reduc$ or decreas$) adj5 (risk or incidence$ or symptom$)).ti,ab. (274974)
41. ((reduc$ or decreas$) adj5 (depress$ or unhapp$ or melanchol$ or despond$ or despair or grief or malaise)).ti,ab. (20945)
42. relaps$.ti,ab. (156870)
43. 38 and (39 or 40 or 41 or 42) (4111)
44. Depression, Postpartum/pc [Prevention & Control] (709)
45. 43 or 44 (4493)
46. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or metaanalysis as topic/ (320381)
47. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. (876797)
48. Random$.ti,ab. (960741)
49. control groups/ or double-blind method/ or single-blind method/ (173101)
50. clinical trial$.ti,ab. (303532)
51. controlled trial$.ti,ab. (178090)
52. meta analy$.ti,ab. (112471)
53. 46 or 47 or 48 or 49 or 50 or 51 or 52 (1780750)
54. 45 and 53 (1002)
55. limit 54 to (english language and yr=“2012 -Current”) (468)
56. remove duplicates from 55 (356)

## PsycInfo (Ovid)

Database: PsycINFO <1806 to November Week 1 2016>

------------------------------------------------------------

1. Pregnancy/ (18756)
2. Expectant Mothers/ (573)
3. Prenatal Care/ (1533)
4. Perinatal Period/ (2146)
5. Postnatal Period/ (3984)
6. Mother Child Relations/ (19695)
7. pregnan$.ti,ab,id. (39159)
8. prenatal.ti,ab,id. (16223)
9. pre natal.ti,ab,id. (220)
10. perinatal.ti,ab,id. (8450)
11. peri natal.ti,ab,id. (60)
12. antenatal.ti,ab,id. (2684)
13. ante natal.ti,ab,id. (47)
14. antepartum.ti,ab,id. (265)
15. ante partum.ti,ab,id. (10)
16. postnatal.ti,ab,id. (17080)
17. post natal.ti,ab,id. (911)
18. postpartum.ti,ab,id. (9487)
19. post partum.ti,ab,id. (1007)
20. new mother$.ti,ab,id. (1033)
21. puerperal.ti,ab,id. (466)
22. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 (89141)
23. Major Depression/ (102486)
24. Dysthymic disorder/ (1435)
25. Anxiety/ (51869)
26. depress$.ti,ab,id. (253298)
27. dysthym$.ti,ab,id. (3611)
28. (anxiety or anxious).ti,ab,id. (167498)
29. blues.ti,ab,id. (732)
30. 23 or 24 or 25 or 26 or 27 or 28 or 29 (360539)
31. 22 and 30 (14844)
32. Postpartum Depression/ (3795)
33. Postpartum Psychosis/ (253)
34. 31 or 32 or 33 (15356)
35. exp Primary Mental Health Prevention/ or exp Prevention/ (50315)
36. prevent$.ti,ab,id. (182188)
37. ((reduc$ or decreas$) adj5 (risk or incidence$ or symptom$)).ti,ab,id. (41878)
38. ((reduc$ or decreas$) adj5 (depress$ or unhapp$ or melanchol$ or despond$ or despair or grief or malaise)).ti,ab,id. (13253)
39. relaps$.ti,ab,id. (24172)
40. “Promotion & Maintenance of Health & Wellness”.cc. (50991)
41. or/35–40 (276948)
42. random$.ti,ab,id,hw. (160247)
43. placebo$.ti,ab,hw,id. (35549)
44. controlled trial$.ti,ab,id,hw. (28545)
45. clinical trial$.ti,ab,id,hw. (30506)
46. meta analy$.ti,ab,hw,id. (25774)
47. Clinical Trial.md. (16459)
48. 42 or 43 or 44 or 45 or 46 or 47 (218953)
49. 34 and 41 and 48 (410)
50. limit 49 to (english language and yr=“2012 -Current”) (194)

## Pubmed, publisher-supplied

Search | Query
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((#9) AND publisher[sb]) AND English[Language]) AND (“2012/01/01”[Date - Publication]: “3000”[Date - Publication])
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #7 AND #8
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search random*[tiab] OR clinical trial*[tiab] OR controlled trial*[tiab] OR meta analy*[tiab] OR metaanaly*[tiab] OR systematic[sb]
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 AND #2 AND #6
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #3 OR #4 OR #5
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search relaps*[tiab]
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((prevent*[tiab]) OR ((reduc*[tiab] OR decreas*[tiab]) AND (risk[tiab] OR incidence*[tiab] OR symptom*[tiab] OR depress*[tiab] OR unhapp*[tiab] OR melanchol*[tiab] OR despond*[tiab] OR despair[tiab] OR grief[tiab] OR malaise[tiab]))
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search prevent*[tiab]
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search depress*[tiab] OR dysthym*[tiab] OR anxiety[tiab] OR anxious[tiab] OR blues[tiab] OR mental[tiab] OR mood[tiab] OR psycholog*[tiab] OR psychiat*[tiab])
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (pregnan*[tiab] OR prenatal[tiab] OR pre natal[tiab] OR perinatal[tiab] OR peri natal[tiab] OR antenatal[tiab] OR ante natal[tiab] OR antepartum[tiab] OR ante partum[tiab] OR postnatal[tiab] OR post natal[tiab] OR postpartum[tiab] OR post partum[tiab] OR mother*[tiab] OR maternal[tiab] OR puerperal[tiab])

### Existing Systematic Reviews Search

Sources searched (2012-present) | Number of items retrieved
Agency for Healthcare Research and Quality | 2 (see links below)
American Psychiatric Association | 0
American Psychological Association | 0
BMJ Clinical Evidence | × (see links below)
Campbell Collaboration | ×
Canadian Agency for Drugs and Technologies in Health | × (see links below)
Cochrane Database of Systematic Reviews | 14 (see attached file)
Database of Abstracts of Reviews of Effects | 5 (see attached file)
Health Technology Assessment (Centre for Reviews and Dissemination) | 2(see attached file)
Institute of Medicine | ×(see link below)
National Institute for Health and Clinical Excellence | × (see links below)
NHS Health Technology Assessment Programme | × (see links below)
PsycINFO | × (see attached file – RIS format)
PubMed/Medline | ×/×(see attached files)

### AHRQ

Efficacy and Safety of Screening for Postpartum Depression – April 2013

http://www.effectivehealthcare.ahrq.gov/ehc/products/379/1437/postpartum-screening-report-130409.pdf

Treatment of Depression During Pregnancy and the Postpartum Period

[Research Protocol – Mar 2013]

http://effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=1447

### BMJ Clinical Evidence

Depression in adults: drug and physical treatments – May 2011

http://clinicalevidence.bmj.com/x/systematic-review/1003/overview.html

Postnatal depression – January 2009

http://clinicalevidence.bmj.com/x/systematic-review/1407/overview.html

### Canadian Agency for Drugs and Technologies in Health

Group Therapy for Mood Disorders: A Review of the Clinical Effectiveness – November 2009

http://www.cadth.ca/media/pdf/L0139_Group_Therapy_Mood_Disorder_final.pdf

Neurofeedback and Biofeedback for Post-Traumatic Stress Disorder, Generalized

Anxiety Disorder, and Depression: A Review of the Clinical Evidence and Guidelines – June 2012

http://www.cadth.ca/media/pdf/htis/june-2012/RC0361%20Neurofeedback%20-%20final.pdf

Self-Directed Cognitive Behavioural Therapy for Adults with Diagnosis of Depression: Systematic Review of Clinical Effectiveness, Cost-Effectiveness, and Guidelines – December 2010

http://www.cadth.ca/en/products/cadth-overviews/vol-1-issue-4/vol-1-issue-4-25

The Emotional Freedom Technique for the Treatment of Post-traumatic Stress Disorder, Depression, or Anxiety: A Review of the Clinical Evidence (In Progress, no link available)

https://www.cadth.ca/emotional-freedom-technique-treatment-post-traumatic-stress-disorder-depression-or-anxiety-review

### Cochrane Database of Systematic Reviews Issue 11 of 12, November 2015

ID | Search Hits
#1 | pregnan*:ti,ab,kw 28738
#2 | prenatal:ti,ab,kw 3657
#3 | pre natal:ti,ab,kw 51
#4 | perinatal:ti,ab,kw 2728
#5 | peri natal:ti,ab,kw 8
#6 | antenatal:ti,ab,kw 1833
#7 | ante natal:ti,ab,kw 22
#8 | antepartum:ti,ab,kw 265
#9 | ante partum:ti,ab,kw 18
#10 | postnatal:ti,ab,kw 2051
#11 | post natal:ti,ab,kw 151
#12 | postpartum:ti,ab,kw 3905
#13 | post partum:ti,ab,kw 671
#14 | (new next mother*):ti,ab,kw 81
#15 | puerperal:ti,ab,kw 796
#16 | ^65-#15^ 33110
#17 | depress*:ti,ab,kw 43819
#18 | dysthym*:ti,ab,kw 602
#19 | (anxiety or anxious):ti,ab,kw 23397
#20 | blues:ti,ab,kw 51
#21 | #17 or #18 or #19 or #20 57569
#22 | prevent*:ti,ab,kw 85274
#23 | (risk near/5 reduc*):ti,ab,kw 16896
#24 | #22 or #23 96176
#25 | #16 and #21 and #24 Publication Year from 2012 to 2014, in Cochrane Reviews (Reviews and Protocols) 14

### Database of Abstracts of Reviews of Effect (Via Cochrane) : Issue 2 of 4, April 2015

ID | Search Hits
#1 | pregnan*:ti,ab,kw 28738
#2 | prenatal:ti,ab,kw 3657
#3 | pre natal:ti,ab,kw 51
#4 | perinatal:ti,ab,kw 2728
#5 | peri natal:ti,ab,kw 8
#6 | antenatal:ti,ab,kw 1833
#7 | ante natal:ti,ab,kw 22
#8 | antepartum:ti,ab,kw 265
#9 | ante partum:ti,ab,kw 18
#10 | postnatal:ti,ab,kw 2051
#11 | post natal:ti,ab,kw 151
#12 | postpartum:ti,ab,kw 3905
#13 | post partum:ti,ab,kw 671
#14 | (new next mother*):ti,ab,kw 81
#15 | puerperal:ti,ab,kw 796
#16 | ^65-#15^ 33110
#17 | depress*:ti,ab,kw 43819
#18 | dysthym*:ti,ab,kw 602
#19 | (anxiety or anxious):ti,ab,kw 23397
#20 | blues:ti,ab,kw 51
#21 | #17 or #18 or #19 or #20 57569
#22 | prevent*:ti,ab,kw 85274
#23 | (risk near/5 reduc*):ti,ab,kw 16896
#24 | #22 or #23 96176
#25 | #16 and #21 and #24 Publication Year from 2012 to 2014, in Other Reviews 5

### Health Technology Assessment (via Cochrane) Issue 4 of 4, October 2015

ID | Search Hits
#1 | pregnan*:ti,ab,kw 28738
#2 | prenatal:ti,ab,kw 3657
#3 | pre natal:ti,ab,kw 51
#4 | perinatal:ti,ab,kw 2728
#5 | peri natal:ti,ab,kw 8
#6 | antenatal:ti,ab,kw 1833
#7 | ante natal:ti,ab,kw 22
#8 | antepartum:ti,ab,kw 265
#9 | ante partum:ti,ab,kw 18
#10 | postnatal:ti,ab,kw 2051
#11 | post natal:ti,ab,kw 151
#12 | postpartum:ti,ab,kw 3905
#13 | post partum:ti,ab,kw 671
#14 | (new next mother*):ti,ab,kw 81
#15 | puerperal:ti,ab,kw 796
#16 | ^65-#15^ 33110
#17 | depress*:ti,ab,kw 43819
#18 | dysthym*:ti,ab,kw 602
#19 | (anxiety or anxious):ti,ab,kw 23397
#20 | blues:ti,ab,kw 51
#21 | #17 or #18 or #19 or #20 57569
#22 | prevent*:ti,ab,kw 85274
#23 | (risk near/5 reduc*):ti,ab,kw 16896
#24 | #22 or #23 96176
#25 | #16 and #21 and #24 Publication Year from 2012 to 2014, in Technology Assessments 2

### Institute of Medicine

Depression in Parents, Parenting, and Children: Opportunities to Improve Identification, Treatment, and Prevention – June 2009

http://www.iom.edu/Reports/2009/Depression-in-Parents-Parenting-and-Children-Opportunities-to-Improve-Identification-Treatment-and-Prevention.aspx

### Medline

Database: Ovid MEDLINE(R) without Revisions <1996 to September Week 4 2013>, Ovid MEDLINE(R) Daily Update <October 01, 2013>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <October 01, 2013>

Search Strategy:

------------------------------------------------------------

1. Depression/dh, dt, pc, rh, su, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Surgery, Therapy] (12681)
2. Depression, Postpartum/dh, dt, pc, rh, su, th (1128)
3. Depressive Disorder, Major/dh, dt, pc, rh, su, th (8165)
4. Dysthymic Disorder/dh, dt, pc, rh, su, th (407)
5. Depressive Disorder/dh, dt, pc, rh, su, th (14336)
6. Depressive Disorder, Treatment-Resistant/dh, dt, pc, rh, su, th (128)
7. Depression/ (45946)
8. Depression, Postpartum/ (3034)
9. Depressive Disorder, Major/ (16264)
10. Dysthymic Disorder/ (944)
11. Depressive Disorder/ (31568)
12. Depressive Disorder, Treatment-Resistant/ (139)
13. Mass screening/ (52456)
14. screen$.ti,ab. (337919)
15. 13 or 14 (351410)
16. 7 or 8 or 9 or 10 or 11 or 12 (93445)
17. 15 and 16 (6735)
18. 1 or 2 or 3 or 4 or 5 or 6 or 17 (40224)
19. limit 18 to “all adult (19 plus years)” (23707)
20. limit 19 to systematic reviews (924)
21. limit 20 to (english language and yr=“2008 -Current”) (475)
22. depression.ti. (43238)
23. depressed.ti. (4336)
24. depressive.ti. (12510)
25. dysthymi$.ti. (331)
26. antidepress$.ti. (9846)
27. mood.ti. (6811)
28. 22 or 23 or 24 or 25 or 26 or 27 (73074)
29. limit 28 to systematic reviews (3042)
30. limit 29 to (“in data review” or in process or “pubmed not medline”) (230)
31. limit 30 to (english language and yr=“2008 -Current”) (208)
32. 21 or 31 (683)
33. remove duplicates from 32 (681)

### NHS HTA Programme

Lithium or an atypical anti-psychotic in the management of treatment resistant depression: systematic review and economic evaluation – Estimated publication October 2013

http://www.hta.ac.uk/2599

The clinical effectiveness and cost-effectiveness of low-intensity psychological interventions for the secondary prevention of relapse after depression: a systematic review – June 2012

http://www.journalslibrary.nihr.ac.uk/hta/volume-16/issue-28

Methods to identify postnatal depression in primary care: an integrated evidence synthesis and value of information analysis – July 2009

http://www.journalslibrary.nihr.ac.uk/hta/volume-13/issue-36

### NICE

Major depressive disorder - vortioxetine – In development, expected August 2014

http://guidance.nice.org.uk/TAG/351

http://www.nice.org.uk/guidance/ta367

Agomelatine for the treatment of major depressive episodes – July 2011

http://www.nice.org.uk/guidance/TA231

Common mental health disorders: Identification and pathways to care – May 2011

http://publications.nice.org.uk/common-mental-health-disorders-cg123

Depression in adults quality standard – March 2011

http://publications.nice.org.uk/depression-in-adults-quality-standard-qs8

Vagus nerve stimulation for treatment-resistant depression – December 2009

http://www.nice.org.uk/_gs/searchtracker/GUIDANCE/12149

http://www.nice.org.uk/guidance/ipg330 ??

Depression in adults (update) – October (http://www.nice.org.uk/_gs/searchtracker/GUIDANCE/12329) 2009

http://www.nice.org.uk/_gs/searchtracker/GUIDANCE/12329

http://www.nice.org.uk/guidance/cg90

Depression with a chronic physical health problem – October 2009

http://www.nice.org.uk/_gs/searchtracker/GUIDANCE/12327

http://www.nice.org.uk/guidance/cg91

### PubMed search strategy

#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #2 AND publisher[sb] Filters: Publication date from 2008/01/01 to 2013/12/31; English
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 AND systematic[sb]
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search depression[ti] OR depressive[ti] OR depressed[ti] OR antidepress*[ti] OR dysthymi*[ti] OR mood[ti]

### PsycINFO <1806 to October Week 1 2013>

Search Strategy:

------------------------------------------------------------

1. major depression/ (82407)
2. dysthymic disorder/ (1357)
3. Postpartum Depression/ (2888)
4. Recurrent Depression/ (597)
5. Treatment Resistant Depression/ (1378)
6. “Depression (Emotion)”/ (21125)
7. 1 or 2 or 3 or 4 or 5 or 6 (107139)
8. limit 7 to “300 adulthood <age 18 yrs and older>” (66533)
9. limit 8 to “0830 systematic review” (97)
10. limit 8 to 1200 meta analysis (197)
11. 9 or 10 (269)
12. limit 11 to (english language and yr=“2008 -Current”) (125)
13. from 12 keep 1–125 (125)

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Included | Excluded
Aim/Objective | Studies on counseling or pharmacologic interventions to prevent perinatal depression | Studies restricted to screening for and treatment of depression during pregnancy or in the postpartum period
Populations | - Pregnant women and mothers ≤1 year postpartum; may target women with mental health symptoms or disorders (see exceptions under exclusion criteria); - A priori subpopulations of interest: adolescents, racial/ethnic minority women, women with a history of depressive disorders (including perinatal depression), women with anxiety disorders, women with low socioeconomic status, and single mothers | - Studies limited to perinatal women currently experiencing or being treated for a depressive episode; - Studies limited to women with psychotic or development disorders (e.g., schizophrenia, pervasive development disorder); - Studies limited to women with a medical condition (e.g., HIV/AIDS); - Nonhuman populations; - Studies limited to spouses or domestic partners; - Studies limited to persons in institutions (e.g., psychiatric inpatients, prison inmates, juvenile detention centers, foster homes, group homes); - Studies limited to persons in long-term care or residential facilities; Studies in mixed populations that include >50% of any of the above populations will be excluded
Interventions | Counseling and pharmacologic interventions to reduce the risk of perinatal depression initiated during pregnancy or the first year postpartum, including:; - Counseling (e.g., cognitive behavioral therapy, interpersonal psychotherapy, nondirective counseling, debriefing), psychoeducation, or other supportive interventions (e.g., peer mentoring, support group); - Care delivery models targeting improved mental health outcomes; - Prophylactic use of antidepressants (i.e., tricyclic antidepressants and monoamine oxidase inhibitors, selective serotonin reuptake inhibitors, selective norepinephrine reuptake inhibitors, dopamine reuptake inhibitors, 5-HT2A receptor antagonists, serotonin reuptake inhibitors, tetracyclic antidepressants); harms will only be examined for medications with evidence of benefit to prevent perinatal depression; - Widely available physical activity or complementary and alternative therapies (i.e., massage, acupuncture, hypnosis, light exposure, yoga); - Hormonal therapy (e.g., estrogen, oxytocin, thyroxine) | - Interventions within closed preexisting social networks (e.g., church, worksite); - General parenting education without a mental health component (e.g., prenatal or infant care classes); - Other prophylactic medications
Comparators | - No intervention; - Usual care; - Waitlist; - Attention control; - Minimal intervention (e.g., usual care limited to no more than 15 minutes of information); - Placebo required for medication trials | Active intervention (i.e., comparative effectiveness)
Outcomes | KQ 1: Maternal health outcomes:; - Depression incidence or symptoms (required); - Suicide deaths, attempts, or ideation, including self-harm; - Health-related quality of life, including stress and anxiety; - Functioning, including maternal functioning; - Health care utilization (e.g., emergency department visits, hospital admissions); - Breastfeeding; - Marital discord and family function; Infant/child health outcomes (for newborn infant or other children in the family):; - Mortality; - Neglect or abuse; - Physical, social, emotional, or behavioral development; - Attachment or bonding; - Achievement of recognized developmental milestones; - Health care utilization (e.g., emergency department visits, hospital admissions, neonatal intensive care unit stays/number of days); KQ 2:; - Reduced satisfaction with care; - Care avoidance; - Maternal or fetal/infant harms related to antidepressant use:; - Gestational diabetes or metabolic effects; - Preeclampsia; - Vaginal bleeding or postpartum hemorrhage; - Miscarriage or spontaneous abortion; - Infant serotonin syndrome or serotonin withdrawal syndrome; - Infant cardiac effects; - Infant seizures or convulsions; - Perinatal death; - Preterm birth or early gestational age; - Low birth weight or small for gestational age; - Neonatal respiratory distress; - Neonatal pulmonary hypertension; - Major malformations, including cardiac malformations; - Neonatal intensive care unit admission; - Other harms reported in trials of treatment benefit; - Other harms of psychotherapy | KQ 1: Maternal behavioral outcomes (e.g., increase in physical activity)
Timing of Outcome Assessment | KQ 1: ≥6 weeks after baseline assessment or intervention initiation KQ 2: Any time after the intervention is initiated | KQ 1: <6 weeks after baseline assessment or intervention initiation
Settings | - Primary care settings (e.g., internal medicine, family medicine, obstetrics/gynecology, pediatrics, family planning clinics, military health clinics, school-based health clinics, midwifery services); - Virtual (e.g., Web-based interventions); - Mental health clinic settings; - Community settings; - Home visits | - Correctional facilities; - School classrooms; - Worksites; - Inpatient/residential/long-term care facilities; - Emergency departments
Study Designs | KQ 1: Randomized, controlled trials; controlled clinical trials KQ 2: Systematic reviews; meta-analyses; randomized, controlled trials; controlled clinical trials; and large comparative cohort studies (for harms of antidepressant use only) | All other study designs (e.g., case report, case series)
Countries | Countries categorized as “Very High” on the 2014 Human Development Index, as defined by the United Nations Development Programme | Countries not categorized as “Very High” on the Human Development Index
Languages | English | Languages other than English
Quality | Fair or good, according to design-specific USPSTF criteria | Poor, according to design-specific USPSTF criteria

Abbreviations: KQ = Key Question; USPSTF = U.S. Preventive Services Task Force

Appendix A Table 2 Quality Assessment Criteria^*^

Study Design | Adapted Quality Criteria
Randomized and non-randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^65^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.

Appendix A Figure 1 Analytic Framework

Abbreviations: HrQoL = health-related quality of life

Appendix A Figure 1 is the analytic framework that depicts the two Key Questions to be addressed in the systematic review. The figure illustrates how interventions to prevent perinatal depression may result in improved health outcomes for both the mother and infant/child, including decreased incidence of perinatal depression and perinatal depression symptoms; improved health-related quality of life and functioning for mothers; and improved health, physical and psychosocial development, and decreased mortality, neglect, and abuse for infant/child (KQ1). Additionally, the figure depicts whether interventions to prevent perinatal depression are associated with any harms (KQ2).

Appendix A Figure 2 Literature Flow Diagram

*Studies may appear in more than one Key Question

This figure is a flow chart that summarizes the search and selection of articles in the review. There were 79 citations identified through a search to identify existing systematic reviews. There were 790 citations identified through literature databases. An additional 167 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 1,036 unique citations were screened at the title/abstract stage. The full text of 247 citations were examined for inclusion for one or more of the Key Questions. For Key Question 1, 50 studies (64 publications) were included. For Key Question 2, 2 studies (2 publications) were included. Reasons for excluding the other articles are available in Appendix D.