# References

1 National Institute on Alcohol Abuse and Alcoholism (NIAAA). Helping Patients Who Drink Too Much: A Clinician’s Guide. Rockville, MD: National Institutes of Health; 2005.
2 US Surgeon General. U.S. Surgeon General Releases Advisory on Alcohol Use in Pregnancy. https://wayback.archive-it.org/3926/20140421162517/http:/www.surgeongeneral.gov/news/2005/02/sg02222005.html. Accessed July, 2018.
3 American College of Obstetricians and Gynecologists. FAQ: Fetal Alcohol Spectrum Disorders (FASDs). https://www.acog.org/About-ACOG/ACOG-Departments/Tobacco-Alcohol-and-Substance-Abuse/Fetal-Alcohol-Spectrum-Disorders-Prevention-Program/FAQs#safetime. Accessed July, 2018.
4 American Academy of Pediatrics. AAP Says No Amount of Alcohol Should be Considered Safe During Pregnancy. https://www.aap.org/en-us/about-the-aap/aap-press-room/pages/AAP-Says-No-Amount-of-Alcohol-Should-be-Considered-Safe-During-Pregnancy.aspx. Accessed July, 2018.
5 National Institute on Alcohol Abuse and Alcoholism. Fetal Alcohol Exposure. https://www.niaaa.nih.gov/alcohol-health/fetal-alcohol-exposure. Accessed July, 2018.
6 National Institute on Alcohol Abuse and Alcoholism (NIAAA). Alcohol Screening and Brief Intervention for Youth: A Practitioner’s Guide. National Institutes of Health; 2011.
7 Dawson DA. Defining risk drinking. Alcohol Res Health. 2011;34(2):144–56. PMID: 22330212.22330212
8 Rehm J, Gmel GE, Sr., Gmel G, . The relationship between different dimensions of alcohol use and the burden of disease-an update. Addiction. 2017;112(6):968–1001. PMID: 28220587. 10.1111/add.13757 28220587
9 Grant BF, Chou SP, Saha TD, . Prevalence of 12-month alcohol use, high-risk drinking, and DSM-IV alcohol use disorder in the United States, 2001-2002 to 2012-2013: results from the National Epidemiologic Survey on Alcohol and Related Conditions. JAMA Psychiatry. 2017;74(9):911–23. PMID: 28793133. 10.1001/jamapsychiatry.2017.2161 28793133
10 Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Division of Population Health. BRFSS Prevalence & Trends Data. https://www.cdc.gov/brfss/brfssprevalence/. Accessed July, 2018.
11 Center for Behavioral Health Statistics and Quality. Results from the 2016 National Survey on Drug Use and Health: Detailed Tables. https://www.samhsa.gov/data/sites/default/files/NSDUH-DetTabs-2016/NSDUH-DetTabs-2016.pdf. Accessed October 2, 2017.
12 Centers for Disease Control and Prevention. Early Release of Selected Estimates Based on Data From the January–June 2013 National Health Interview Survey National Center for Health Statistics 2013.
13 Dwyer-Lindgren L, Flaxman AD, Ng M, . Drinking Patterns in US Counties From 2002 to 2012. Am J Public Health. 2015;105(6):1120–7. PMID: 25905846. 10.2105/AJPH.2014.302313 25905846
14 Breslow RA, Castle IP, Chen CM, . Trends in Alcohol Consumption Among Older Americans: National Health Interview Surveys, 1997 to 2014. Alcohol Clin Exp Res. 2017;41(5):976–86. PMID: 28340502. 10.1111/acer.13365 28340502
15 Center for Behavioral Health Statistics and Quality. Results from the 2015 National Survey on Drug Use and Health (HHS Publication No. SMA 16-4984, NSDUH Series H-51). 2016. PMID: None.
16 Erol A, Karpyak VM. Sex and gender-related differences in alcohol use and its consequences: Contemporary knowledge and future research considerations. Drug Alcohol Depend. 2015;156:1–13. PMID: 26371405. 10.1016/j.drugalcdep.2015.08.023 26371405
17 Grant BF, Saha TD, Ruan WJ, . Epidemiology of DSM-5 Drug Use Disorder: Results From the National Epidemiologic Survey on Alcohol and Related Conditions-III. JAMA Psychiatry. 2015:1–9. PMID: 26580136. 10.1001/jamapsychiatry.2015.2132 26580136
18 Han BH, Moore AA, Sherman S, . Demographic trends of binge alcohol use and alcohol use disorders among older adults in the United States, 2005-2014. Drug Alcohol Depend. 2017;170:198–207. 10.1016/j.drugalcdep.2016.11.003 27979428
19 Witbrodt J, Mulia N, Zemore SE, . Racial/ethnic disparities in alcohol-related problems: differences by gender and level of heavy drinking. Alcohol Clin Exp Res. 2014;38(6):1662–70. 10.1111/acer.12398 24730475
20 Cunningham JK, Solomon TA, Muramoto ML. Alcohol use among Native Americans compared to whites: Examining the veracity of the ‘Native American elevated alcohol consumption’ belief. Drug Alcohol Depend. 2016;160:65–75. 10.1016/j.drugalcdep.2015.12.015 26868862
21 Stahre M, Roeber J, Kanny D, . Contribution of excessive alcohol consumption to deaths and years of potential life lost in the United States. Prev Chronic Dis. 2014;11:E109. PMID: 24967831. 10.5888/pcd11.130293 24967831
22 Xu J, Murphy SL, Kochanek KD, . Deaths: Final Data for 2013. National vital statistics reports: from the Centers for Disease Control and Prevention, National Center for Health Statistics, National Vital Statistics System. 2016;64(2):1–119.
23 Nelson DE, Jarman DW, Rehm J, . Alcohol-attributable cancer deaths and years of potential life lost in the United States. Am J Public Health. 2013;103(4):641–8. PMID: 23409916. 10.2105/AJPH.2012.301199 23409916
24 World Health Organization. Guidelines for the Identification and Management of Substance Use and Substance Use Disorders in Pregnancy. Geneva, Switzerland: World Health Organization; 2014.
25 Ismail S, Buckley S, Budacki R, . Screening, diagnosing and prevention of fetal alcohol syndrome: is this syndrome treatable? Dev Neurosci. 2010;32(2):91–100. PMID: 20551645. 10.1159/000313339 20551645
26 Caputo C, Wood E, Jabbour L. Impact of fetal alcohol exposure on body systems: A systematic review. Birth Defects Res C Embryo Today. 2016;108(2):174–80. PMID: 27297122. 10.1002/bdrc.21129 27297122
27 National Institute on Alcohol Abuse and Alcoholism (NIAAA). Alcohol Facts and Statistics. https://www.niaaa.nih.gov/alcohol-health/overview-alcohol-consumption/alcohol-facts-and-statistics. Accessed September 26, 2017.
28 Hingson RW, Zha W, Weitzman ER. Magnitude of and trends in alcohol-related mortality and morbidity among U.S. college students ages 18-24, 1998-2005. J Stud Alcohol Drugs Suppl. 2009(16):12–20. PMID: 19538908. 10.15288/jsads.2009.s16.12 19538908
29 Hingson R, Heeren T, Winter M, . Magnitude of alcohol-related mortality and morbidity among U.S. college students ages 18-24: changes from 1998 to 2001. Annu Rev Public Health. 2005;26:259–79. PMID: 15760289. 10.1146/annurev.publhealth.26.021304.144652 15760289
30 Wechsler H, Dowdall GW, Maenner G, . Changes in binge drinking and related problems among American college students between 1993 and 1997. Results of the Harvard School of Public Health College Alcohol Study. J Am Coll Health. 1998;47(2):57–68. PMID: 9782661. 10.1080/07448489809595621 9782661
31 Sacks JJ, Gonzales KR, Bouchery EE, . 2010 National and State Costs of Excessive Alcohol Consumption. Am J Prev Med. 2015;49(5):e73–9. PMID: 26477807. 10.1016/j.amepre.2015.05.031 26477807
32 US Department of Health, Human Services and US Department of Agriculture. 2015–2020 Dietary Guidelines for Americans. Washington, DC: US Department of Health and Human Services and US Department of Agriculture; 2015.
33 Di Castelnuovo A, Costanzo S, Bagnardi V, . Alcohol dosing and total mortality in men and women: an updated meta-analysis of 34 prospective studies. Arch Intern Med. 2006;166(22):2437–45. PMID: 17159008. 10.1001/archinte.166.22.2437 17159008
34 Corrao G, Bagnardi V, Zambon A, . A meta-analysis of alcohol consumption and the risk of 15 diseases. Preventive medicine. 2004;38(5):613–9. PMID: 15066364. 10.1016/j.ypmed.2003.11.027 15066364
35 Chartier KG, Vaeth PA, Caetano R. Focus on: ethnicity and the social and health harms from drinking. Alcohol Res. 2013;35(2):229–37.24881331
36 Schafer J, Caetano R, Cunradi CB. A path model of risk factors for intimate partner violence among couples in the United States. Journal of interpersonal violence. 2004;19(2):127–42. 10.1177/0886260503260244 15005998
37 Oetzel J, Duran B. Intimate partner violence in American Indian and/or Alaska Native communities: a social ecological framework of determinants and interventions. Am Indian Alsk Native Ment Health Res. 2004;11(3):49–68.15536589
38 Wahab S, Olson L. Intimate partner violence and sexual assault in Native American communities. Trauma Violence Abuse. 2004;5(4):353–66. 10.1177/1524838004269489 15361588
39 Stinson FS, Grant BF, Dufour MC. The critical dimension of ethnicity in liver cirrhosis mortality statistics. Alcohol Clin Exp Res. 2001;25(8):1181–7.11505049
40 Yoon YH, Chen, C.M. Liver Cirrhosis Mortality in the United States: National, State, and Regional Trends, 2000-2013. Arlington, VA: National Institute of Alcohol Abuse and Alcoholism; 2016.
41 Polednak AP. Secular trend in U.S. black-white disparities in selected alcohol-related cancer incidence rates. Alcohol Alcohol. 2007;42(2):125–30. 10.1093/alcalc/agl121 17255152
42 Yang AL, Vadhavkar S, Singh G, . Epidemiology of alcohol-related liver and pancreatic disease in the United States. Arch Intern Med. 2008;168(6):649–56. 10.1001/archinte.168.6.649 18362258
43 Caetano R, Vaeth PA, Chartier KG, . Epidemiology of drinking, alcohol use disorders, and related problems in US ethnic minority groups. Handb Clin Neurol. 2014;125:629–48. 10.1016/B978-0-444-62619-6.00037-9 25307601
44 Keyes KM, Liu XC, Cerda M. The role of race/ethnicity in alcohol-attributable injury in the United States. Epidemiol Rev. 2012;34:89–102. 10.1093/epirev/mxr018 21930592
45 Office of the Surgeon General. Facing Addiction in America: The Surgeon General’s Report on Alcohol, Drugs, and Health. Washington DC: US Dept of Health and Human Services; 2016. PMID: None.
46 Liang W, Chikritzhs T. Age at first use of alcohol and risk of heavy alcohol use: a population-based study. Biomed Res Int. 2013;2013:721761. PMID: 24471139. 10.1155/2013/721761 24471139
47 Dawson DA, Goldstein RB, Chou SP, . Age at first drink and the first incidence of adult-onset DSM-IV alcohol use disorders. Alcohol Clin Exp Res. 2008;32(12):2149–60. PMID: 18828796. 10.1111/j.1530-0277.2008.00806.x 18828796
48 Shin SH, Chung Y, Rosenberg RD. Identifying Sensitive Periods for Alcohol Use: The Roles of Timing and Chronicity of Child Physical Abuse. Alcohol Clin Exp Res. 2016;40(5):1020–9. PMID: 27079899. 10.1111/acer.13038 27079899
49 Sartor CE, Waldron M, Duncan AE, . Childhood sexual abuse and early substance use in adolescent girls: the role of familial influences. Addiction. 2013;108(5):993–1000. PMID: 23316725. 10.1111/add.12115 23316725
50 Nelson EC, Heath AC, Lynskey MT, . Childhood sexual abuse and risks for licit and illicit drug-related outcomes: a twin study. Psychol Med. 2006;36(10):1473–83. PMID: 16854248. 10.1017/S0033291706008397 16854248
51 Kendler KS, Bulik CM, Silberg J, . Childhood sexual abuse and adult psychiatric and substance use disorders in women: an epidemiological and cotwin control analysis. Arch Gen Psychiatry. 2000;57(10):953–9. PMID: 11015813. 10.1001/archpsyc.57.10.953 11015813
52 Substance Abuse and Mental Health Services Administration. Behavioral Health Trends in the United States: Results from the 2014 National Survey on Drug Use and Health. US Department of Health and Human Services; 2014.
53 Grant BF, Stinson FS, Dawson DA, . Prevalence and co-occurrence of substance use disorders and independent mood and anxiety disorders: results from the National Epidemiologic Survey on Alcohol and Related Conditions. Arch Gen Psychiatry. 2004;61(8):807–16. PMID: 15289279. 10.1001/archpsyc.61.8.807 15289279
54 Sorensen HJ, Manzardo AM, Knop J, . The contribution of parental alcohol use disorders and other psychiatric illness to the risk of alcohol use disorders in the offspring. Alcohol Clin Exp Res. 2011;35(7):1315–20. PMID: 21676003. 10.1111/j.1530-0277.2011.01467.x 21676003
55 Mellentin AI, Brink M, Andersen L, . The risk of offspring developing substance use disorders when exposed to one versus two parent(s) with alcohol use disorder: A nationwide, register-based cohort study. J Psychiatr Res. 2016;80:52–8. PMID: 27295121. 10.1016/j.jpsychires.2016.06.001 27295121
56 Kendler KS, Edwards AC, Gardner CO. Sex differences in the pathways to symptoms of alcohol use disorder: a study of opposite-sex twin pairs. Alcohol Clin Exp Res. 2015;39(6):998–1007. PMID: 25845269. 10.1111/acer.12694 25845269
57 Centers for Disease Control and Prevention. Alcohol and Public Health: Alcohol-Related Disease Impact (ARDI). https://nccd.cdc.gov/DPH_ARDI/Default/Report.aspx?T=AAM&P=f6d7eda7-036e-4553-9968-9b17ffad620e&R=d7a9b303-48e9-4440-bf47-070a4827e1fd&M=8E1C5233-5640-4EE8-9247-1ECA7DA325B9&F=&D. Accessed September 26, 2017.
58 National Institute on Alcohol Abuse and Alcoholism (NIAAA). Harmful Interactions: Mixing alcohol with medicines. National Institutes of Health; 2014.
59 Solberg LI, Maciosek MV, Edwards NM. Primary care intervention to reduce alcohol misuse ranking its health impact and cost effectiveness. Am J Prev Med. 2008;34(2):143–52. PMID: 18201645. 10.1016/j.amepre.2007.09.035 18201645
60 Epstein AJ, Barry CL, Fiellin DA, . Consumers’ Valuation of Primary Care-Based Treatment Options for Mental and Substance Use Disorders. Psychiatric services. 2015;66(8):772–4. PMID: 25930049. 10.1176/appi.ps.201500077 25930049
61 Saitz R. Screening for unhealthy use of alcohol and other drugs in primary care. UpToDate. 2015.
62 Humeniuk R, Henry-Edwards S, Ali R, . The Alcohol, Smoking and Substance Involvement Screening Test (ASSIST): Manual for use in primary care. 2010.
63 Substance Abuse and Mental Health Services Administration. Screening, Brief Intervention, and Referral to Treatment (SBIRT). Accessed 07/13/2016.
64 Substance Abuse and Mental Health Services Administration, National Institute on Alcohol Abuse and Alcoholism. Medication for the Treatment of Alcohol Use Disorder: A Brief Guide. Rockville, MD: 2015.
65 Manuel JK, Satre DD, Tsoh J, . Adapting Screening, Brief Intervention, and Referral to Treatment for Alcohol and Drugs to Culturally Diverse Clinical Populations. J Addict Med. 2015;9(5):343–51. PMID: 26428359. 10.1097/ADM.0000000000000150 26428359
66 Moyer VA, Preventive Services Task F. Screening and behavioral counseling interventions in primary care to reduce alcohol misuse: U.S. preventive services task force recommendation statement. Ann Intern Med. 2013;159(3):210–8. 10.7326/0003-4819-159-3-201308060-00652 23698791
67 National Institute on Alcohol Abuse and Alcoholism (NIAAA). NIAA Alcohol Treatment Navigator. https://alcoholtreatment.niaaa.nih.gov/. Accessed Mar 7, 2018.
68 Harris BR, Yu J. Attitudes, perceptions and practice of alcohol and drug screening, brief intervention and referral to treatment: a case study of New York State primary care physicians and non-physician providers. Public Health. 2016. PMID: 27311990. 10.1016/j.puhe.2016.05.007 27311990
69 Le KB, Johnson JA, Seale JP, . Primary care residents lack comfort and experience with alcohol screening and brief intervention: a multi-site survey. J Gen Intern Med. 2015;30(6):790–6. PMID: 25666210. 10.1007/s11606-015-3184-y 25666210
70 McKnight-Eily LR, Okoro CA, Mejia R, . Screening for Excessive Alcohol Use and Brief Counseling of Adults — 17 States and the District of Columbia, 2014. MMWR Morb Mortal Wkly Rep. 2017;66:313–9. PMID: 28358798. 10.15585/mmwr.mm6612a1 28358798
71 McKnight-Eily LR, Liu Y, Brewer RD, . Vital signs: communication between health professionals and their patients about alcohol use-44 states and the District of Columbia, 2011. MMWR Morb Mortal Wkly Rep. 2014;63(1):16–22. PMID: 24402468.24402468
72 Hingson RW, Heeren T, Edwards EM, . Young adults at risk for excess alcohol consumption are often not asked or counseled about drinking alcohol. J Gen Intern Med. 2012;27(2):179–84. PMID: 21935753. 10.1007/s11606-011-1851-1 21935753
73 Hettema J, Cockrell S, Russo J, . Missed Opportunities: Screening and Brief Intervention for Risky Alcohol Use in Women’s Health Settings. J Womens Health (Larchmt). 2015;24(8):648–54. PMID: 26230758. 10.1089/jwh.2014.4961 26230758
74 Sterling S, Kline-Simon AH, Wibbelsman C, . Screening for adolescent alcohol and drug use in pediatric health-care settings: predictors and implications for practice and policy. Addict Sci Clin Pract. 2012;7:13. PMID: 23186254. 10.1186/1940-0640-7-13 23186254
75 McGregor K, Hall J. Brief electronic screening for adolescents in primary health care. Journal of adolescent health. 2014;54(2 suppl. 1):S92–s3. PMID: None. 10.1016/j.jadohealth.2013.10.197 24560083
76 Department of Veterans Affairs. VA/DoD Clinical Practice Guideline for the Management of Substance Use Disorders. Washington DC: Department of Defense; 2015.
77 US Surgeon General. National Prevention Strategy: Preventing Drug Abuse and Excessive Alcohol Use. http://www.surgeongeneral.gov/priorities/prevention/strategy/preventing-abuse.pdf. Accessed August 23, 2017.
78 Willenbring ML, Massey SH, Gardner MB. Helping patients who drink too much: an evidence-based guide for primary care clinicians. Am Fam Physician. 2009;80(1):44–50. PMID: 19621845.19621845
79 American Society of Addiction Medicine. Public Policy Statement on Screening for Addiction in Primary Care Settings. http://www.asam.org/docs/default-source/public-policy-statements/1screening-for-addiction-rev-10-97.pdf?sfvrsn=0. Accessed August 23, 2017.
80 Centers for Disease Control and Prevention. Planning and Implementing Screening and Brief Intervention for Risky Alcohol Use: A Step-by-Step Guide for Primary Care Practices. https://www.cdc.gov/ncbddd/fasd/documents/alcoholsbiimplementationguide.pdf. Accessed Mar 7, 2018.
81 Levy SJ, Williams JF, Committee On Substance USE, . Substance Use Screening, Brief Intervention, and Referral to Treatment. Pediatrics. 2016;138(1). 10.1542/peds.2016-1211
82 The American College of Obstetrics and Gynecologists. At-Risk Drinking and Alcohol Dependence: Obstetric and Gynecologic Implications. Obstet Gynecol. 2011;118(2):383–8. PMID: 21775870. 10.1097/AOG.0b013e31822c9906 21775870
83 Jonas DE, Garbutt JC, Amick HR, . Behavioral counseling after screening for alcohol misuse in primary care: a systematic review and meta-analysis for the U.S. Preventive Services Task Force. Ann Intern Med. 2012;157(9):645–54. PMID: 23007881. 10.7326/0003-4819-157-9-201211060-00544 23007881
84 Cook RL, Chung T, Kelly TM, . Alcohol screening in young persons attending a sexually transmitted disease clinic. Comparison of AUDIT, CRAFFT, and CAGE instruments. J Gen Intern Med. 2005;20(1):1–6. PMID: 15693920. 10.1111/j.1525-1497.2005.40052.x 15693920
85 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
86 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529–36. PMID: 22007046. 10.7326/0003-4819-155-8-201110180-00009 22007046
87 Newcombe RG. Two-sided confidence intervals for the single proportion: comparison of seven methods. Stat Med. 1998;17(8):857–72. PMID: 9595616.9595616
88 Wilson EB. Probable inference, the law of succession, and statistical inference. Journal of the American Statistical Association. 1927;22(158):209–12. PMID: None.
89 DerSimonian R, Kacker R. Random-effects model for meta-analysis of clinical trials: an update. Contemp Clin Trials. 2007;28(2):105–14. PMID: 16807131. 10.1016/j.cct.2006.04.004 16807131
90 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629–34. PMID: 9310563. 10.1136/bmj.315.7109.629 9310563
91 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: None.
92 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
93 Aalto M, Alho H, Halme JT, . AUDIT and its abbreviated versions in detecting heavy and binge drinking in a general population survey. Drug Alcohol Depend. 2009;103(1-2):25–9. PMID: 19395203. 10.1016/j.drugalcdep.2009.02.013 19395203
94 Aalto M, Alho H, Halme JT, . The Alcohol Use Disorders Identification Test (AUDIT) and its derivatives in screening for heavy drinking among the elderly. Int J Geriatr Psychiatry. 2011;26(9):881–5. PMID: 20661878. 10.1002/gps.2498 20661878
95 Aertgeerts B, Buntinx F, Bande-Knops J, . The value of CAGE, CUGE, and AUDIT in screening for alcohol abuse and dependence among college freshmen. Alcohol Clin Exp Res. 2000;24(1):53–7. PMID: 10656193. 10.1111/j.1530-0277.2000.tb04553.x 10656193
96 Bartoli F, Crocamo C, Biagi E, . Clinical utility of a single-item test for DSM-5 alcohol use disorder among outpatients with anxiety and depressive disorders. Drug Alcohol Depend. 2016;165:283–7. PMID: 27318372. 10.1016/j.drugalcdep.2016.06.003 27318372
97 Boschloo L, Vogelzangs N, Smit JH, . The performance of the Alcohol Use Disorder Identification Test (AUDIT) in detecting alcohol abuse and dependence in a population of depressed or anxious persons. J Affect Disord. 2010;126(3):441–6. PMID: 20537398. 10.1016/j.jad.2010.04.019 20537398
98 Bradley KA, Bush KR, Epler AJ, . Two brief alcohol-screening tests from the Alcohol Use Disorders Identification Test (AUDIT): validation in a female Veterans Affairs patient population. Arch Intern Med. 2003;163(7):821–9. PMID: 12695273. 10.1001/archinte.163.7.821 12695273
99 Buchsbaum DG, Welsh J, Buchanan RG, . Screening for drinking problems by patient self-report. Even ‘safe’ levels may indicate a problem. Arch Intern Med. 1995;155(1):104–8. PMID: 7802509. 10.1001/archinte.1995.00430010112015 7802509
100 Bull LB, Kvigne VL, Leonardson GR, . Validation of a self-administered questionnaire to screen for prenatal alcohol use in Northern Plains Indian women. Am J Prev Med. 1999;16(3):240–3. PMID: 10198664. 10.1016/S0749-3797(98)00158-5 10198664
101 Chung T, Smith GT, Donovan JE, . Drinking frequency as a brief screen for adolescent alcohol problems. Pediatrics. 2012;129(2):205–12. PMID: 22218839. 10.1542/peds.2011-1828 22218839
102 Clark DB, Martin CS, Chung T, . Screening for Underage Drinking and Diagnostic and Statistical Manual of Mental Disorders, 5th Edition Alcohol Use Disorder in Rural Primary Care Practice. J Pediatr. 2016;173:214–20. PMID: 27059911. 10.1016/j.jpeds.2016.02.047 27059911
103 Clements R. A critical evaluation of several alcohol screening instruments using the CIDI-SAM as a criterion measure. Alcohol Clin Exp Res. 1998;22(5):985–93. PMID: 9726267. 10.1111/j.1530-0277.1998.tb03693.x 9726267
104 Crawford EF, Fulton JJ, Swinkels CM, . Diagnostic efficiency of the AUDIT-C in U.S. veterans with military service since September 11, 2001. Drug Alcohol Depend. 2013;132(1-2):101–6. PMID: 23465735. 10.1016/j.drugalcdep.2013.01.012 23465735
105 D’Amico EJ, Parast L, Meredith LS, . Screening in Primary Care: What Is the Best Way to Identify At-Risk Youth for Substance Use? Pediatrics. 2016;138(6). PMID: 27940696. 10.1542/peds.2016-1717 27940696
106 Dawson DA, Grant BF, Stinson FS, . Effectiveness of the derived Alcohol Use Disorders Identification Test (AUDIT-C) in screening for alcohol use disorders and risk drinking in the US general population. Alcohol Clin Exp Res. 2005;29(5):844–54. PMID: 15897730. 10.1097/01.ALC.0000164374.32229.A2 15897730
107 Dawson DA, Smith SM, Saha TD, . Comparative performance of the AUDIT-C in screening for DSM-IV and DSM-5 alcohol use disorders. Drug Alcohol Depend. 2012;126(3):384–8. PMID: 22728044. 10.1016/j.drugalcdep.2012.05.029 22728044
108 Degenhardt LJ, Conigrave KM, Wutzke SE, . The validity of an Australian modification of the AUDIT questionnaire. Drug Alcohol Rev. 2001;20(2):143–54. PMID: None. 10.1080/09595230120058533
109 Demartini KS, Carey KB. Optimizing the use of the AUDIT for alcohol screening in college students. Psychol Assess. 2012;24(4):954–63. PMID: 22612646. 10.1037/a0028519 22612646
110 Foxcroft DR, Smith LA, Thomas H, . Accuracy of Alcohol Use Disorders Identification Test for detecting problem drinking in 18-35 year-olds in England: method comparison study. Alcohol Alcohol. 2015;50(2):244–50. PMID: 25534931. 10.1093/alcalc/agu095 25534931
111 Gache P, Michaud P, Landry U, . The Alcohol Use Disorders Identification Test (AUDIT) as a screening tool for excessive drinking in primary care: reliability and validity of a French version. Alcohol Clin Exp Res. 2005;29(11):2001–7. PMID: 16340457. 10.1097/01.alc.0000187034.58955.64 16340457
112 Gomez A, Conde A, Santana JM, . Diagnostic usefulness of brief versions of Alcohol Use Disorders Identification Test (AUDIT) for detecting hazardous drinkers in primary care settings. J Stud Alcohol Drugs. 2005;66(2):305–8. PMID: 15957683. 10.15288/jsa.2005.66.305 15957683
113 Gomez A, Conde A, Santana JM, . The diagnostic usefulness of AUDIT and AUDIT-C for detecting hazardous drinkers in the elderly. Aging Ment Health. 2006;10(5):558–61. PMID: 16938691. 10.1080/13607860600637729 16938691
114 Gryczynski J, Kelly SM, Mitchell SG, . Validation and performance of the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) among adolescent primary care patients. Addiction. 2015;110(2):240–7. PMID: 25311148. 10.1111/add.12767 25311148
115 Gual A, Segura L, Contel M, . Audit-3 and audit-4: effectiveness of two short forms of the alcohol use disorders identification test. Alcohol Alcohol. 2002;37(6):591–6. PMID: 12414553.12414553
116 Harris SK, Knight JR, Jr., Van Hook S, . Adolescent substance use screening in primary care: Validity of computer self-administered versus clinician-administered screening. Subst Abus. 2016;37(1):197–203. PMID: 25774878. 10.1080/08897077.2015.1014615 25774878
117 Isaacson JH, Butler R, Zacharek M, . Screening with the Alcohol use Disorders Identification Test (AUDIT) in an inner-city population. J Gen Intern Med. 1994;9(10):550–3. PMID: 7823225.7823225
118 Kelly SM, Gryczynski J, Mitchell SG, . Validity of brief screening instrument for adolescent tobacco, alcohol, and drug use. Pediatrics. 2014;133(5):819–26. PMID: 24753528. 10.1542/peds.2013-2346 24753528
119 Knight J, Sherritt L, Harris S, . Validity of brief alcohol screening tests among adolescents: a comparison of the AUDIT, POSIT, CAGE, and CRAFFT. Alcohol Clin Exp Res. 2003;27(1):67–73. PMID: 12544008. 10.1097/01.ALC.0000046598.59317.3A 12544008
120 Kokotailo PK, Egan J, Gangnon R, . Validity of the alcohol use disorders identification test in college students. Alcohol Clin Exp Res. 2004;28(6):914–20. PMID: 15201634. 10.1097/01.ALC.0000128239.87611.F5 15201634
121 Kumar PC, Cleland CM, Gourevitch MN, . Accuracy of the Audio Computer Assisted Self Interview version of the Alcohol, Smoking and Substance Involvement Screening Test (ACASI ASSIST) for identifying unhealthy substance use and substance use disorders in primary care patients. Drug Alcohol Depend. 2016;165:38–44. PMID: 27344194. 10.1016/j.drugalcdep.2016.05.030 27344194
122 Levola J, Aalto M. Screening for At-Risk Drinking in a Population Reporting Symptoms of Depression: A Validation of the AUDIT, AUDIT-C, and AUDIT-3. Alcohol Clin Exp Res. 2015;39(7):1186–92. PMID: 26058472. 10.1111/acer.12763 26058472
123 Levy S, Dedeoglu F, Gaffin JM, . A Screening Tool for Assessing Alcohol Use Risk among Medically Vulnerable Youth. PloS one. 2016;11(5):e0156240. PMID: 27227975. 10.1371/journal.pone.0156240 27227975
124 McCann BS, Simpson TL, Ries R, . Reliability and validity of screening instruments for drug and alcohol abuse in adults seeking evaluation for attention-deficit/hyperactivity disorder. Am J Addict. 2000;9(1):1–9. PMID: 10914288. 10.1080/10550490050172173 10914288
125 McGinnis KA, Justice AC, Kraemer KL, . Comparing alcohol screening measures among HIV-infected and -uninfected men. Alcohol Clin Exp Res. 2013;37(3):435–42. PMID: 23050632. 10.1111/j.1530-0277.2012.01937.x 23050632
126 McNeely J, Strauss SM, Saitz R, . A Brief Patient Self-administered Substance Use Screening Tool for Primary Care: Two-site Validation Study of the Substance Use Brief Screen (SUBS). Am J Med. 2015;128(7):784.e9–19. PMID: 25770031. 10.1016/j.amjmed.2015.02.007 25770031
127 Northrup TF, Malone PS, Follingstad D, . Using item response theory to improve alcohol dependence screening for African American and White male and female college students. Addict Disord Their Treat. 2013;12(2):99–109. 10.1097/ADT.0b013e3182627431
128 Piccinelli M, Tessari E, Bortolomasi M, . Efficacy of the alcohol use disorders identification test as a screening tool for hazardous alcohol intake and related disorders in primary care: a validity study. BMJ. 1997;314(7078):420–4. PMID: 9040389. 10.1136/bmj.314.7078.420 9040389
129 Rumpf HJ, Hapke U, Meyer C, . Screening for alcohol use disorders and at-risk drinking in the general population: psychometric performance of three questionnaires. Alcohol Alcohol. 2002;37(3):261–8. PMID: 12003915.12003915
130 Rumpf HJ, Wohlert T, Freyer-Adam J, . Screening questionnaires for problem drinking in adolescents: performance of AUDIT, AUDIT-C, CRAFFT and POSIT. Eur Addict Res. 2013;19(3):121–7. PMID: 23183686. 10.1159/000342331 23183686
131 Santis R, Garmendia ML, Acuna G, . The Alcohol Use Disorders Identification Test (AUDIT) as a screening instrument for adolescents. Drug Alcohol Depend. 2009;103(3):155–8. PMID: 19423240. 10.1016/j.drugalcdep.2009.01.017 19423240
132 Seale JP, Boltri JM, Shellenberger S, . Primary care validation of a single screening question for drinkers. J Stud Alcohol Drugs. 2006;67(5):778–84. PMID: 16847548. 10.15288/jsa.2006.67.778 16847548
133 Smith PC, Schmidt SM, Allensworth-Davies D, . Primary care validation of a single-question alcohol screening test. [Erratum appears in J Gen Intern Med. 2010 Apr;25(4):375]. J Gen Intern Med. 2009;24(7):783–8. PMID: 19247718. 10.1007/s11606-009-0928-6 19247718
134 Volk RJ, Steinbauer JR, Cantor SB, . The Alcohol Use Disorders Identification Test (AUDIT) as a screen for at-risk drinking in primary care patients of different racial/ethnic backgrounds. Addiction. 1997;92(2):197–206. PMID: 9158231. 10.1111/j.1360-0443.1997.tb03652.x 9158231
135 Lopez MB, Lichtenberger A, Conde K, . Psychometric Properties of Brief Screening Tests for Alcohol Use Disorders during Pregnancy in Argentina. Revista Brasileira de Ginecologia e Obstetricia. 2017;39(7):322–9. PMID: 28609804. 10.1055/s-0037-1603744 28609804
136 McNeely J, Wu LT, Subramaniam G, . Performance of the Tobacco, Alcohol, Prescription Medication, and Other Substance Use (TAPS) Tool for Substance Use Screening in Primary Care Patients. Ann Intern Med. 2016. PMID: 27595276. 10.7326/m16-0317 27595276
137 Bradley KA, DeBenedetti AF, Volk RJ, . AUDIT-C as a brief screen for alcohol misuse in primary care. Alcohol Clin Exp Res. 2007;31(7):1208–17. PMID: 17451397. 10.1111/j.1530-0277.2007.00403.x 17451397
138 Bush KR, Kivlahan DR, Davis TM, . The TWEAK is weak for alcohol screening among female Veterans Affairs outpatients. Alcohol Clin Exp Res. 2003;27(12):1971–8. PMID: 14691385. 10.1097/01.ALC.0000099262.50094.98 14691385
139 Dawson DA, Pulay AJ, Grant BF. A comparison of two single-item screeners for hazardous drinking and alcohol use disorder. Alcohol Clin Exp Res. 2010;34(2):364–74. PMID: 19951291. 10.1111/j.1530-0277.2009.01098.x 19951291
140 Frank D, DeBenedetti AF, Volk RJ, . Effectiveness of the AUDIT-C as a screening test for alcohol misuse in three race/ethnic groups. J Gen Intern Med. 2008;23(6):781–7. PMID: 18421511. 10.1007/s11606-008-0594-0 18421511
141 Johnson JA, Lee A, Vinson D, . Use of AUDIT-based measures to identify unhealthy alcohol use and alcohol dependence in primary care: a validation study. Alcohol Clin Exp Res. 2013;37: Suppl 1:E253–9. PMID: 22834916. 10.1111/j.1530-0277.2012.01898.x 22834916
142 McNeely J, Cleland CM, Strauss SM, . Validation of Self-Administered Single-Item Screening Questions (SISQs) for Unhealthy Alcohol and Drug Use in Primary Care Patients. J Gen Intern Med. 2015;30(12):1757–64. PMID: 25986138 10.1007/s11606-015-3391-6 25986138
143 Northrup TF. Effective measurement of problematic drinking for college students: Reducing differential item functioning across gender and race. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2010;70(7-B):4492. PMID: None.
144 Saitz R, Cheng DM, Allensworth-Davies D, . The ability of single screening questions for unhealthy alcohol and other drug use to identify substance dependence in primary care. J Stud Alcohol Drugs. 2014;75(1):153–7. PMID: 24411807. 10.15288/jsad.2014.75.153 24411807
145 Steinbauer JR, Cantor SB, Holzer CE, 3rd, . Ethnic and sex bias in primary care screening tests for alcohol use disorders. Ann Intern Med. 1998;129(5):353–62. PMID: 9735062.9735062
146 Wu LT, McNeely J, Subramaniam GA, . Design of the NIDA clinical trials network validation study of tobacco, alcohol, prescription medications, and substance use/misuse (TAPS) tool. Contemp Clin Trials. 2016;50:90–7. PMID: 27444426. 10.1016/j.cct.2016.07.013 27444426
147 Gryczynski J, McNeely J, Wu LT, . Validation of the TAPS-1: A Four-Item Screening Tool to Identify Unhealthy Substance Use in Primary Care. J Gen Intern Med. 2017. PMID: 28550609. 10.1007/s11606-017-4079-x 28550609
148 Anderson P, Scott E. The effect of general practitioners’ advice to heavy drinking men. Br J Addict. 1992;87(6):891–900. PMID: 1525531. 10.1111/j.1360-0443.1992.tb01984.x 1525531
149 Bischof G, Grothues JM, Reinhardt S, . Evaluation of a telephone-based stepped care intervention for alcohol-related disorders: a randomized controlled trial. Drug Alcohol Depend. 2008;93(3):244–51. PMID: 18054443. 10.1016/j.drugalcdep.2007.10.003 18054443
150 Grothues JM, Bischof G, Reinhardt S, . Effectiveness of brief alcohol interventions for general practice patients with problematic drinking behavior and comorbid anxiety or depressive disorders. Drug Alcohol Depend. 2008;94(1-3):214–20. PMID: 18207336. 10.1016/j.drugalcdep.2007.11.015 18207336
151 Reinhardt S, Bischof G, Grothues J, . Gender differences in the efficacy of brief interventions with a stepped care approach in general practice patients with alcohol-related disorders. Alcohol Alcohol. 2008;43(3):334–40. PMID: 18263901. 10.1093/alcalc/agn004 18263901
152 Curry SJ, Ludman EJ, Grothaus LC, . A randomized trial of a brief primary-care-based intervention for reducing at-risk drinking practices. Health Psychol. 2003;22(2):156–65. PMID: 12683736. 10.1037/0278-6133.22.2.156 12683736
153 Fleming MF, Barry KL, Manwell LB, . Brief physician advice for problem alcohol drinkers. A randomized controlled trial in community-based primary care practices. JAMA. 1997;277(13):1039–45. PMID: 9091691. 10.1001/jama.1997.03540370029032 9091691
154 Fleming MF, Mundt MP, French MT, . Benefit-cost analysis of brief physician advice with problem drinkers in primary care settings. Med Care. 2000;38(1):7–18. PMID: 10630716. 10.1097/00005650-200001000-00003 10630716
155 Fleming MF, Mundt MP, French MT, . Brief physician advice for problem drinkers: long-term efficacy and benefit-cost analysis. Alcohol Clin Exp Res. 2002;26(1):36–43. PMID: 11821652. 10.1111/j.1530-0277.2002.tb02429.x 11821652
156 Grossberg PM, Brown DD, Fleming MF. Brief physician advice for high-risk drinking among young adults. Ann Fam Med. 2004;2(5):474–80. PMID: 15506584. 10.1370/afm.122 15506584
157 Fleming MF, Manwell LB, Barry KL, . Brief physician advice for alcohol problems in older adults: a randomized community-based trial. J Fam Pract. 1999;48(5):378–84. PMID: 10334615.10334615
158 Fleming MF, Lund MR, Wilton G, . The Healthy Moms Study: the efficacy of brief alcohol intervention in postpartum women. Alcohol Clin Exp Res. 2008;32(9):1600–6. PMID: 18627361. 10.1111/j.1530-0277.2008.00738.x 18627361
159 Wilton G, Moberg DP, Fleming MF. The effect of brief alcohol intervention on postpartum depression. MCN Am J Matern Child Nurs. 2009;34(5):297–302. PMID: 19713798. 10.1097/01.NMC.0000360422.06486.c4 19713798
160 Fleming MF, Balousek SL, Grossberg PM, . Brief physician advice for heavy drinking college students: a randomized controlled trial in college health clinics. J Stud Alcohol Drugs. 2010;71(1):23–31. PMID: 20105410. 10.15288/jsad.2010.71.23 20105410
161 Kypri K, Saunders JB, Williams SM, . Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. 2004;99(11):1410–7. PMID: 15500594. 10.1111/j.1360-0443.2004.00847.x 15500594
162 Kypri K, Langley JD, Saunders JB, . Randomized controlled trial of web-based alcohol screening and brief intervention in primary care. Arch Intern Med. 2008;168(5):530–6. PMID: 18332300. 10.1001/archinternmed.2007.109 18332300
163 Maisto SA, Conigliaro J, McNeil M, . Effects of two types of brief intervention and readiness to change on alcohol use in hazardous drinkers. J Stud Alcohol. 2001;62(5):605–14. PMID: 11702799. 10.15288/jsa.2001.62.605 11702799
164 Gordon AJ, Conigliaro J, Maisto SA, . Comparison of consumption effects of brief interventions for hazardous drinking elderly. Subst Use Misuse. 2003;38(8):1017–35. PMID: 12901447. 10.1081/JA-120017649 12901447
165 Ockene JK, Adams A, Hurley TG, . Brief physician- and nurse practitioner-delivered counseling for high-risk drinkers: does it work? Arch Intern Med. 1999;159(18):2198–205. PMID: 10527297. 10.1001/archinte.159.18.2198 10527297
166 Ockene JK, Reed GW, Reiff-Hekking S. Brief patient-centered clinician-delivered counseling for high-risk drinking: 4-year results. Ann Behav Med. 2009;37(3):335–42. PMID: 19707840. 10.1007/s12160-009-9108-5 19707840
167 Reiff-Hekking S, Ockene JK, Hurley TG, . Brief physician and nurse practitioner-delivered counseling for high-risk drinking. Results at 12-month follow-up. J Gen Intern Med. 2005;20(1):7–13. PMID: 15693921. 10.1111/j.1525-1497.2005.21240.x 15693921
168 Rubio G, Jimenez-Arriero MA, Martinez I, . Efficacy of physician-delivered brief counseling intervention for binge drinkers. Am J Med. 2010;123(1):72–8. PMID: 20102995. 10.1016/j.amjmed.2009.08.012 20102995
169 Saitz R, Horton NJ, Sullivan LM, . Addressing alcohol problems in primary care: a cluster randomized, controlled trial of a systems intervention. The screening and intervention in primary care (SIP) study. Ann Intern Med. 2003;138(5):372–82. PMID: 12614089. 10.7326/0003-4819-138-5-200303040-00006 12614089
170 Schaus JF, Sole ML, McCoy TP, . Alcohol screening and brief intervention in a college student health center: a randomized controlled trial. J Stud Alcohol Drugs Suppl. 2009(16):131–41. PMID: 19538921. 10.15288/jsads.2009.s16.131 19538921
171 Scott E, Anderson P. Randomized controlled trial of general practitioner intervention in women with excessive alcohol consumption. Drug Alcohol Rev. 1990;10(4):313–21. PMID: 16818295. 10.1080/09595239100185371 16818295
172 Senft RA, Polen MR, Freeborn DK, . Brief intervention in a primary care setting for hazardous drinkers. Am J Prev Med. 1997;13(6):464–70. PMID: 9415794.9415794
173 Freeborn DK, Polen MR, Hollis JF, . Screening and brief intervention for hazardous drinking in an HMO: effects on medical care utilization. J Behav Health Serv Res. 2000;27(4):446–53. PMID: 11070638.11070638
174 Wallace P, Cutler S, Haines A. Randomised controlled trial of general practitioner intervention in patients with excessive alcohol consumption. BMJ. 1988;297(6649):663–8. PMID: 3052668.3052668
175 Richmond R, Heather N, Wodak A, . Controlled evaluation of a general practice-based brief intervention for excessive drinking. Addiction. 1995;90(1):119–32. PMID: 7888970. 10.1046/j.1360-0443.1995.90111915.x 7888970
176 Moore A, Blow F, Hoffing M, . Primary care-based intervention to reduce at-risk drinking in older adults: a randomized controlled trial. Addiction. 2010;106(1):111–20. PMID: 21143686. 10.1111/j.1360-0443.2010.03229.x.21143686
177 Lin J, Karno M, Tang L, . Do health educator telephone calls reduce at-risk drinking among older adults in primary care? J Gen Intern Med. 2010;25(4):334–9. PMID: 20101471. 10.1007/s11606-009-1223-2 20101471
178 Kypri K, Langley JD, Saunders J, . Assessment may conceal therapeutic benefit: findings from a randomized controlled trial for hazardous drinking. Addiction. 2007;102(1):62–70. PMID: 17207124. 10.1111/j.1360-0443.2006.01632.x 17207124
179 Mundt MP, French MT, Roebuck M, . Brief physician advice for problem drinking among older adults: an economic analysis of costs and benefits. J Stud Alcohol. 2005;66(3):389–94. PMID: 16047528. 10.15288/jsa.2005.66.389 16047528
180 Manwell LB, Fleming MF, Mundt MP, . Treatment of problem alcohol use in women of childbearing age: results of a brief intervention trial. Alcohol Clin Exp Res. 2000;24(10):1517–24. PMID: 11045860. 10.1111/j.1530-0277.2000.tb04570.x 11045860
181 Chang G, Wilkins-Haug L, Berman S, . Brief intervention for alcohol use in pregnancy: a randomized trial. Addiction. 1999;94(10):1499–508. PMID: 10790902. 10.1046/j.1360-0443.1999.941014996.x 10790902
182 Maisto SA, Conigliaro J, McNeil M, . The relationship between eligibility criteria for participation in alcohol brief intervention trials and other alcohol and health-related variables. Am J Addict. 2001;10(3):218–31. PMID: 11579620. 10.1080/105504901750532102 11579620
183 Ettner SL, Xu H, Duru OK, . The effect of an educational intervention on alcohol consumption, at-risk drinking, and health care utilization in older adults: the Project SHARE study. J Stud Alcohol Drugs. 2014;75(3):447–57. PMID: 24766757. 10.15288/jsad.2014.75.447 24766757
184 Rubio DM, Day NL, Conigliaro J, . Brief motivational enhancement intervention to prevent or reduce postpartum alcohol use: a single-blinded, randomized controlled effectiveness trial. J Subst Abuse Treat. 2014;46(3):382–9. PMID: 24315218. 10.1016/j.jsat.2013.10.009 24315218
185 Crawford MJ, Sanatinia R, Barrett B, . The clinical effectiveness and cost-effectiveness of brief intervention for excessive alcohol consumption among people attending sexual health clinics: a randomised controlled trial (SHEAR). Health Technol Assess. 2014;18(30):1–48. PMID: 24813652. 10.3310/hta18300 24813652
186 Kaner E, Bland M, Cassidy P, . Effectiveness of screening and brief alcohol intervention in primary care (SIPS trial): pragmatic cluster randomised controlled trial. BMJ. 2013;346:e8501. PMID: 23303891. 10.1136/bmj.e8501 23303891
187 Baer JS, Kivlahan DR, Blume AW, . Brief intervention for heavy-drinking college students: 4-year follow-up and natural history. Am J Public Health. 2001;91(8):1310–6. PMID: 11499124.11499124
188 Burge SK, Amodei N, Elkin B, . An evaluation of two primary care interventions for alcohol abuse among Mexican-American patients. Addiction. 1997;92(12):1705–16. PMID: 9581003. 10.1111/j.1360-0443.1997.tb02891.x 9581003
189 Carey KB, Carey MP, Maisto SA, . Brief motivational interventions for heavy college drinkers: A randomized controlled trial. J Consult Clin Psychol. 2006;74(5):943–54. PMID: 17032098. 10.1037/0022-006X.74.5.943 17032098
190 Chang G, Fisher ND, Hornstein MD, . Brief intervention for women with risky drinking and medical diagnoses: a randomized controlled trial. J Subst Abuse Treat. 2011;41(2):105–14. PMID: 21489738. 10.1016/j.jsat.2011.02.011 21489738
191 Chang G, McNamara TK, Orav EJ, . Brief intervention for prenatal alcohol use: a randomized trial. Obstet Gynecol. 2005;105(5 Pt 1):991–8. PMID: 15863535. 10.1097/01.AOG.0000157109.05453.84 15863535
192 Daeppen JB, Bertholet N, Gaume J, . Efficacy of brief motivational intervention in reducing binge drinking in young men: A randomized controlled trial. Drug Alcohol Depend. 2011;113(1):69–75. PMID: 20729010. 10.1016/j.drugalcdep.2010.07.009 20729010
193 Emmen MJ, Schippers GM, Wollersheim H, . Adding psychologist’s intervention to physicians’ advice to problem drinkers in the outpatient clinic. Alcohol Alcohol. 2005;40(3):219–26. PMID: 15699056. 10.1093/alcalc/agh137 15699056
194 Johnsson KO, Berglund M. Comparison between a cognitive behavioural alcohol programme and post-mailed minimal intervention in high-risk drinking university freshmen: results from a randomized controlled trial. Alcohol Alcohol. 2006;41(2):174–80. PMID: 16322100. 10.1093/alcalc/agh243 16322100
195 Kypri K, Hallett J, Howat P, . Randomized controlled trial of proactive web-based alcohol screening and brief intervention for university students. Arch Intern Med. 2009;169(16):1508–14. PMID: 19752409. 10.1001/archinternmed.2009.249 19752409
196 LaBrie JW, Huchting KK, Lac A, . Preventing risky drinking in first-year college women: further validation of a female-specific motivational-enhancement group intervention. J Stud Alcohol Drugs Suppl. 2009(16):77–85. PMID: 19538915. 10.15288/jsads.2009.s16.77 19538915
197 Larimer ME, Lee CM, Kilmer JR, . Personalized mailed feedback for college drinking prevention: a randomized clinical trial. J Consult Clin Psychol. 2007;75(2):285–93. PMID: 17469886. 10.1037/0022-006X.75.2.285 17469886
198 Marlatt GA, Baer JS, Kivlahan DR, . Screening and brief intervention for high-risk college student drinkers: results from a 2-year follow-up assessment. J Consult Clin Psychol. 1998;66(4):604–15. PMID: 9735576. 10.1037/0022-006X.66.4.604 9735576
199 Martens MP, Kilmer JR, Beck NC, . The efficacy of a targeted personalized drinking feedback intervention among intercollegiate athletes: a randomized controlled trial. Psychol Addict Behav. 2010;24(4):660–9. PMID: 20822189. 10.1037/a0020299 20822189
200 Neighbors C, Larimer ME, Lewis MA. Targeting misperceptions of descriptive drinking norms: efficacy of a computer-delivered personalized normative feedback intervention. J Consult Clin Psychol. 2004;72(3):434–47. PMID: 15279527. 10.1037/0022-006X.72.3.434 15279527
201 Neighbors C, Lewis MA, Atkins DC, . Efficacy of web-based personalized normative feedback: a two-year randomized controlled trial. J Consult Clin Psychol. 2010;78(6):898–911. PMID: 20873892. 10.1037/a0020766 20873892
202 O’Connor MJ, Whaley SE. Brief intervention for alcohol use by pregnant women. Am J Public Health. 2007;97(2):252–8. PMID: 17194863. 10.2105/AJPH.2005.077222 17194863
203 Reynolds KD, Coombs DW, Lowe JB, . Evaluation of a self-help program to reduce alcohol consumption among pregnant women. Int J Addict. 1995;30(4):427–43. PMID: 7607777. 10.3109/10826089509048735 7607777
204 Roberts LJ, Neal DJ, Kivlahan DR, . Individual drinking changes following a brief intervention among college students: clinical significance in an indicated preventive context. J Consult Clin Psychol. 2000;68(3):500–5. PMID: 10883566. 10.1037/0022-006X.68.3.500 10883566
205 Turrisi R, Larimer ME, Mallett KA, . A randomized clinical trial evaluating a combined alcohol intervention for high-risk college students. J Stud Alcohol Drugs. 2009;70(4):555–67. PMID: 19515296. 10.15288/jsad.2009.70.555 19515296
206 Aalto M, Saksanen R, Laine P, . Brief intervention for female heavy drinkers in routine general practice: a 3-year randomized, controlled study. Alcohol Clin Exp Res. 2000;24(11):1680–6. PMID: 11104115. 10.1111/j.1530-0277.2000.tb01969.x 11104115
207 Aalto M, Seppa K, Mattila P, . Brief intervention for male heavy drinkers in routine general practice: a three-year randomized controlled study. Alcohol Alcohol. 2001;36(3):224–30. PMID: 11373259. 10.1093/alcalc/36.3.224 11373259
208 Drummond C, Coulton S, James D, . Effectiveness and cost-effectiveness of a stepped care intervention for alcohol use disorders in primary care: pilot study. Br J Psychiatry. 2009;195(5):448–56. PMID: 19880936. 10.1192/bjp.bp.108.056697 19880936
209 Heather N, Campion PD, Neville RG, . Evaluation of a controlled drinking minimal intervention for problem drinkers in general practice (the DRAMS scheme). J R Coll Gen Pract. 1987;37(301):358–63. PMID: 3448228.3448228
210 Haug S, Paz Castro R, Kowatsch T, . Efficacy of a Web- and Text Messaging-Based Intervention to Reduce Problem Drinking in Adolescents: Results of a Cluster-Randomized Controlled Trial. J Consult Clin Psychol. 2016. PMID: 27606700. 10.1037/ccp0000138 27606700
211 Leeman RF, DeMartini KS, Gueorguieva R, . Randomized Controlled Trial of a Very Brief, Multicomponent Web-Based Alcohol Intervention for Undergraduates With a Focus on Protective Behavioral Strategies. J Consult Clin Psychol. 2016. PMID: 27599223. 10.1037/ccp0000132 27599223
212 Ondersma SJ, Svikis DS, Thacker LR, . A randomised trial of a computer-delivered screening and brief intervention for postpartum alcohol use. Drug Alcohol Rev. 2016. PMID: 27004474. 10.1111/dar.12389 27004474
213 Barnes AJ, Xu H, Tseng CH, . The Effect of a Patient-Provider Educational Intervention to Reduce At-Risk Drinking on Changes in Health and Health-Related Quality of Life Among Older Adults: The Project SHARE Study. J Subst Abuse Treat. 2016;60:14–20. PMID: 26254687. 10.1016/j.jsat.2015.06.019 26254687
214 Grossbard JR, Mastroleo NR, Geisner IM, . Drinking norms, readiness to change, and gender as moderators of a combined alcohol intervention for first-year college students. Addict Behav. 2016;52:75–82. PMID: 26363307. 10.1016/j.addbeh.2015.07.028 26363307
215 Mason M, Light J, Campbell L, . Peer Network Counseling with Urban Adolescents: A Randomized Controlled Trial with Moderate Substance Users. J Subst Abuse Treat. 2015;58:16–24. PMID: 26234955. 10.1016/j.jsat.2015.06.013 26234955
216 Montag AC, Brodine SK, Alcaraz JE, . Effect of Depression on Risky Drinking and Response to a Screening, Brief Intervention, and Referral to Treatment Intervention. Am J Public Health. 2015;105(8):1572–6. PMID: 26066915. 10.2105/AJPH.2015.302688 26066915
217 Ondersma SJ, Beatty JR, Svikis DS, . Computer-Delivered Screening and Brief Intervention for Alcohol Use in Pregnancy: A Pilot Randomized Trial. Alcohol Clin Exp Res. 2015;39(7):1219–26. PMID: 26010235. 10.1111/acer.12747 26010235
218 Upshur C, Weinreb L, Bharel M, . A randomized control trial of a chronic care intervention for homeless women with alcohol use problems. J Subst Abuse Treat. 2015;51:19–29. PMID: 25488504. 10.1016/j.jsat.2014.11.001 25488504
219 Crawford MJ, Sanatinia R, Barrett B, . The clinical and cost-effectiveness of brief advice for excessive alcohol consumption among people attending sexual health clinics: a randomised controlled trial. Sex Transm Infect. 2015;91(1):37–43. PMID: 24936090. 10.1136/sextrans-2014-051561 24936090
220 Bertholet N, Cunningham JA, Faouzi M, . Internet-based brief intervention for young men with unhealthy alcohol use: a randomized controlled trial in a general population sample. Addiction. 2015;110(11):1735–43. PMID: 26173842. 10.1111/add.13051 26173842
221 Osterman RL, Carle AC, Ammerman RT, . Single-session motivational intervention to decrease alcohol use during pregnancy. J Subst Abuse Treat. 2014;47(1):10–9. PMID: 24637202. 10.1016/j.jsat.2014.01.009 24637202
222 van der Wulp NY, Hoving C, Eijmael K, . Reducing alcohol use during pregnancy via health counseling by midwives and internet-based computer-tailored feedback: a cluster randomized trial. J Med Internet Res. 2014;16(12):e274. PMID: 25486675. 10.2196/jmir.3493 25486675
223 Collins SE, Kirouac M, Lewis MA, . Randomized controlled trial of web-based decisional balance feedback and personalized normative feedback for college drinkers. J Stud Alcohol Drugs. 2014;75(6):982–92. PMID: 25343656. 10.15288/jsad.2014.75.982 25343656
224 Wilson GB, Wray C, McGovern R, . Intervention to reduce excessive alcohol consumption and improve comorbidity outcomes in hypertensive or depressed primary care patients: two parallel cluster randomized feasibility trials. Trials. 2014;15:235. PMID: 24947447. 10.1186/1745-6215-15-235 24947447
225 Lewis MA, Patrick ME, Litt DM, . Randomized controlled trial of a web-delivered personalized normative feedback intervention to reduce alcohol-related risky sexual behavior among college students. J Consult Clin Psychol. 2014;82(3):429–40. PMID: 24491076. 10.1037/a0035550 24491076
226 Voogt CV, Kuntsche E, Kleinjan M, . The effect of the ‘What Do You Drink’ web-based brief alcohol intervention on self-efficacy to better understand changes in alcohol use over time: randomized controlled trial using ecological momentary assessment. Drug Alcohol Depend. 2014;138:89–97. PMID: 24613632. 10.1016/j.drugalcdep.2014.02.009 24613632
227 LaBrie JW, Lewis MA, Atkins DC, . RCT of web-based personalized normative feedback for college drinking prevention: are typical student norms good enough? J Consult Clin Psychol. 2013;81(6):1074–86. PMID: 23937346. 10.1037/a0034087 23937346
228 Schulz DN, Candel MJ, Kremers SP, . Effects of a Web-based tailored intervention to reduce alcohol consumption in adults: randomized controlled trial. J Med Internet Res. 2013;15(9):e206. PMID: 24045005. 10.2196/jmir.2568 24045005
229 Rossi BV, Chang G, Berry KF, . In vitro fertilization outcomes and alcohol consumption in at-risk drinkers: the effects of a randomized intervention. Am J Addict. 2013;22(5):481–5. PMID: 23952894. 10.1111/j.1521-0391.2013.12019.x 23952894
230 Watson JM, Crosby H, Dale VM, . AESOPS: a randomised controlled trial of the clinical effectiveness and cost-effectiveness of opportunistic screening and stepped care interventions for older hazardous alcohol users in primary care. Health Technol Assess. 2013;17(25):1–158. PMID: 23796191. 10.3310/hta17250 23796191
231 Cunningham JA, Neighbors C, Wild C, . Ultra-brief intervention for problem drinkers: results from a randomized controlled trial. PloS one. 2012;7(10):e48003. PMID: 23110157. 10.1371/journal.pone.0048003 23110157
232 Cleveland MJ, Lanza ST, Ray AE, . Transitions in first-year college student drinking behaviors: does pre-college drinking moderate the effects of parent- and peer-based intervention components? Psychol Addict Behav. 2012;26(3):440–50. PMID: 22061340. 10.1037/a0026130 22061340
233 Hilbink M, Voerman G, van Beurden I, . A randomized controlled trial of a tailored primary care program to reverse excessive alcohol consumption. J Am Board Fam Med. 2012;25(5):712–22. PMID: 22956707. 10.3122/jabfm.2012.05.120070 22956707
234 Hansen AB, Becker U, Nielsen AS, . Internet-based brief personalized feedback intervention in a non-treatment-seeking population of adult heavy drinkers: a randomized controlled trial. J Med Internet Res. 2012;14(4):e98. PMID: 22846542. 10.2196/jmir.1883 22846542
235 Tzilos GK, Sokol RJ, Ondersma SJ. A randomized phase I trial of a brief computer-delivered intervention for alcohol use during pregnancy. J Womens Health (Larchmt). 2011;20(10):1517–24. PMID: 21823917. 10.1089/jwh.2011.2732 21823917
236 Voogt CV, Poelen EA, Kleinjan M, . Targeting young drinkers online: the effectiveness of a web-based brief alcohol intervention in reducing heavy drinking among college students: study protocol of a two-arm parallel group randomized controlled trial. BMC Public Health. 2011;11:231. PMID: 21492412. 10.1186/1471-2458-11-231 21492412
237 Grossbard JR, Mastroleo NR, Kilmer JR, . Substance use patterns among first-year college students: secondary effects of a combined alcohol intervention. J Subst Abuse Treat. 2010;39(4):384–90. PMID: 20817383. 10.1016/j.jsat.2010.07.001 20817383
238 Young CM, Neighbors C, Dibello AM, . Coping motives moderate efficacy of personalized normative feedback among heavy drinking U.S. college students. J Stud Alcohol Drugs. 2016;77(3):495–9. PMID: 27172582. 10.15288/jsad.2016.77.495 27172582
239 Neighbors C, Lewis MA, LaBrie J, . A multisite randomized trial of normative feedback for heavy drinking: Social comparison versus social comparison plus correction of normative misperceptions. J Consult Clin Psychol. 2016;84(3):238–47. PMID: 26727407. 10.1037/ccp0000067 26727407
240 Helstrom AW, Ingram E, Wang W, . Treating heavy drinking in primary care practices: Evaluation of a telephone-based intervention program. Addict Disord Their Treat. 2014;13(3):101–9. PMID: None. 10.1097/ADT.0b013e31827e206c
241 Montag A, Dusek M, Mazzetti A, . Effect of depression on risky drinking and response to a screening, brief intervention, and referral for treatment (SBIRT) intervention. Alcohol Clin Exp Res. 2014;38:257a.24033700
242 Butler C, Simpson S, Hood K, . Training practitioners to deliver opportunistic multiple behaviour change counselling in primary care: a cluster randomised trial. BMJ. 2013;346:f1191. PMID: 23512758. 10.1136/bmj.f1191 23512758
243 Kaner E, Bland M, Cassidy P, . Screening and brief interventions for hazardous and harmful alcohol use in primary care: a cluster randomised controlled trial protocol. BMC Public Health. 2009;9:287. PMID: 19664255. 10.1186/1471-2458-9-287 19664255
244 Coulton S, Bland M, Crosby H, . Effectiveness and Cost-effectiveness of Opportunistic Screening and Stepped-care Interventions for Older Alcohol Users in Primary Care. Alcohol Alcohol. 2017:1–10. PMID: 29016980. 10.1093/alcalc/agx065 27651282
245 Rose GL, Badger GJ, Skelly JM, . A Randomized Controlled Trial of Brief Intervention by Interactive Voice Response. Alcohol Alcohol. 2017;52(3):335–43. PMID: 28069598. 10.1093/alcalc/agw102 28069598
246 Watkins KE, Ober AJ, Lamp K, . Collaborative Care for Opioid and Alcohol Use Disorders in Primary Care: The SUMMIT Randomized Clinical Trial. JAMA Internal Medicine. 2017;177(10):1480–8. PMID: 28846769. 10.1001/jamainternmed.2017.3947 28846769
247 Coulton S, Dale V, Deluca P, . Screening for At-Risk Alcohol Consumption in Primary Care: A Randomized Evaluation of Screening Approaches. Alcohol & Alcoholism. 2017;52(3):312–7. PMID: 28371897. 10.1093/alcalc/agx017 28371897
248 Voogt C, Poelen E, Kleinjan M, . The effectiveness of the ‘what do you drink’ web-based brief alcohol intervention in reducing heavy drinking among students: a two-arm parallel group randomized controlled trial. Alcohol Alcohol. 2013;48(3):312–21. PMID: 23303466. 10.1093/alcalc/ags133 23303466
249 Paz CR, Haug S, Kowatsch T, . Moderators of outcome in a technology-based intervention to prevent and reduce problem drinking among adolescents. Addict Behav. 2017;72:64–71. PMID: 28371696. 10.1016/j.addbeh.2017.03.013 28371696
250 Cohen J. A power primer. Psychological bulletin. 1992;112(1):155.19565683
251 U.S. Department of Veterans Affairs. QUERI – Quality Enhancement Research Initiative. https://www.queri.research.va.gov/tools/alcohol-misuse/alcohol-faqs.cfm. Accessed September 26, 2017.
252 Williams EC, Rubinsky AD, Chavez LJ, . An early evaluation of implementation of brief intervention for unhealthy alcohol use in the US Veterans Health Administration. Addiction. 2014;109(9):1472–81. PMID: 24773590. 10.1111/add.12600 24773590
253 Jonas DE, Miller T, Ratner S, . Implementation and quality improvement of a screening and counseling program for unhealthy alcohol use in an academic general internal medicine practice. J Healthc Qual. 2017;39(1):15–27. PMID: 28045764. 10.1097/JHQ.0000000000000069 28045764
254 Higgins-Biddle JC, Babor TF. A review of the Alcohol Use Disorders Identification Test (AUDIT), AUDIT-C, and USAUDIT for screening in the United States: Past issues and future directions. Am J Drug Alcohol Abuse. 2018:1–9. 10.1080/00952990.2018.1456545
255 Madson MB, Schutts JW, Jordan HR, . Identifying At-Risk College Student Drinkers With the AUDIT-US: A Receiver Operating Characteristic Curve Analysis. Assessment. 2018:1073191118792091. PMID: 30066577. 10.1177/1073191118792091 30066577
256 de Meneses-Gaya C, Zuardi AW, Loureiro SR, . Alcohol Use Disorders Identification Test (AUDIT): An updated systematic review of psychometric properties. Psychology & Neuroscience. 2009;2(1):83–97. PMID: None. 10.3922/j.psns.2009.1.12
257 Tanner-Smith EE, Risser MD. A meta-analysis of brief alcohol interventions for adolescents and young adults: variability in effects across alcohol measures. Am J Drug Alcohol Abuse. 2016;42(2):140–51. PMID: 26905387. 10.3109/00952990.2015.1136638 26905387
258 Tanner-Smith EE, Lipsey MW. Brief alcohol interventions for adolescents and young adults: a systematic review and meta-analysis. J Subst Abuse Treat. 2015;51:1–18. PMID: 25300577. 10.1016/j.jsat.2014.09.001 25300577
259 Samson JE, Tanner-Smith EE. Single-Session Alcohol Interventions for Heavy Drinking College Students: A Systematic Review and Meta-Analysis. J Stud Alcohol Drugs. 2015;76(4):530–43. PMID: 26098028. 10.15288/jsad.2015.76.530 26098028
260 Foxcroft DR, Coombes L, Wood S, . Motivational interviewing for the prevention of alcohol misuse in young adults. Cochrane Database Syst Rev. 2016;7:CD007025. PMID: 27426026. 10.1002/14651858.CD007025.pub4 27426026
261 Donoghue K, Patton R, Phillips T, . The effectiveness of electronic screening and brief intervention for reducing levels of alcohol consumption: a systematic review and meta-analysis. J Med Internet Res. 2014;16(6):e142. PMID: 24892426. 10.2196/jmir.3193 24892426
262 Dedert EA, McDuffie JR, Stein R, . Electronic Interventions for Alcohol Misuse and Alcohol Use Disorders: A Systematic Review. Ann Intern Med. 2015;163(3):205–14. PMID: 26237752. 10.7326/M15-0285 26237752
263 Lopez ML, Iglesias JM, del Valle MO, . Impact of a primary care intervention on smoking, drinking, diet, weight, sun exposure, and work risk in families with cancer experience. Cancer Causes Control. 2007;18(5):525–35. PMID: 17450417. 10.1007/s10552-007-0124-0 17450417
264 Montag AC, Brodine SK, Alcaraz JE, . Preventing alcohol-exposed pregnancy among an American Indian/Alaska Native population: effect of a screening, brief intervention, and referral to treatment intervention. Alcohol Clin Exp Res. 2015;39(1):126–35. PMID: 25623412. 10.1111/acer.12607 25623412
265 Palm A, Olofsson N, Danielsson I, . Motivational interviewing does not affect risk drinking among young women: A randomised, controlled intervention study in Swedish youth health centres. Scand J Public Health. 2016;44(6):611–8. PMID: 27289105. 10.1177/1403494816654047 27289105
266 McCambridge J, Kypri K. Can simply answering research questions change behaviour? Systematic review and meta analyses of brief alcohol intervention trials. PloS one. 2011;6(10):e23748. PMID: 21998626. 10.1371/journal.pone.0023748 21998626
267 Roerecke M, Gual A, Rehm J. Reduction of alcohol consumption and subsequent mortality in alcohol use disorders: systematic review and meta-analyses. J Clin Psychiatry. 2013;74(12):e1181–9. PMID: 24434106. 10.4088/JCP.13r08379 24434106
268 Dick DM, Aliev F, Viken R, . Rutgers alcohol problem index scores at age 18 predict alcohol dependence diagnoses 7 years later. Alcohol Clin Exp Res. 2011;35(5):1011–4. PMID: 21323682. 10.1111/j.1530-0277.2010.01432.x 21323682
269 Paltzer J, Brown RL, Burns M, . Substance Use Screening, Brief Intervention, and Referral to Treatment Among Medicaid Patients in Wisconsin: Impacts on Healthcare Utilization and Costs. J Behav Health Serv Res. 2016. PMID: 27221694. 10.1007/s11414-016-9510-2 27221694
270 Gaume J, McCambridge J, Bertholet N, . Mechanisms of action of brief alcohol interventions remain largely unknown - a narrative review. Front Psychiatr. 2014;5:108. PMID: 25206342. 10.3389/fpsyt.2014.00108 25206342
271 Bertholet N, Palfai T, Gaume J, . Do brief alcohol motivational interventions work like we think they do? Alcohol Clin Exp Res. 2014;38(3):853–9. PMID: 24125097. 10.1111/acer.12274 24125097
272 Ray AE, Kim SY, White HR, . When less is more and more is less in brief motivational interventions: characteristics of intervention content and their associations with drinking outcomes. Psychol Addict Behav. 2014;28(4):1026–40. PMID: 24841183. 10.1037/a0036593 24841183
273 Kan LY, Henderson CE, von Sternberg K, . Does change in alliance impact alcohol treatment outcomes? Subst Abus. 2014;35(1):37–44. PMID: 24588291. 10.1080/08897077.2013.792761 24588291
274 Ornstein SM, Miller PM, Wessell AM, . Integration and sustainability of alcohol screening, brief intervention, and pharmacotherapy in primary care settings. J Stud Alcohol Drugs. 2013;74(4):598–604. PMID: 23739024. 10.15288/jsad.2013.74.598 23739024
275 Rose GL, Badger GJ, Skelly JM, . A Randomized Controlled Trial of IVR-Based Alcohol Brief Intervention to Promote Patient-Provider Communication in Primary Care. J Gen Intern Med. 2016;31(9):996–1003. PMID: 27206539. 10.1007/s11606-016-3692-4 27206539
276 Sterling S, Kline-Simon AH, Satre DD, . Implementation of Screening, Brief Intervention, and Referral to Treatment for Adolescents in Pediatric Primary Care: A Cluster Randomized Trial. JAMA Pediatr. 2015;169(11):e153145. PMID: 26523821. 10.1001/jamapediatrics.2015.3145 26523821
277 Babor TE, Higgins-Biddle J, Dauser D, . Alcohol screening and brief intervention in primary care settings: implementation models and predictors. J Stud Alcohol. 2005;66(3):361–8. PMID: 16047525. 10.15288/jsa.2005.66.361 16047525
278 Mertens JR, Chi FW, Weisner CM, . Physician versus non-physician delivery of alcohol screening, brief intervention and referral to treatment in adult primary care: the ADVISe cluster randomized controlled implementation trial. Addict Sci Clin Pract. 2015;10:26. PMID: 26585638. 10.1186/s13722-015-0047-0 26585638
279 Keurhorst M, van de Glind I, Bitarello do Amaral-Sabadini M, . Implementation strategies to enhance management of heavy alcohol consumption in primary health care: a meta-analysis. Addiction. 2015;110(12):1877–900. PMID: 26234486. 10.1111/add.13088 26234486
280 Anderson P, Bendtsen P, Spak F, . Improving the delivery of brief interventions for heavy drinking in primary health care: outcome results of the Optimizing Delivery of Health Care Intervention (ODHIN) five-country cluster randomized factorial trial. Addiction. 2016. PMID: 27237081. 10.1111/add.13476 27237081
281 Keurhorst M, Heinen M, Colom J, . Strategies in primary healthcare to implement early identification of risky alcohol consumption: why do they work or not? A qualitative evaluation of the ODHIN study. BMC Fam Pract. 2016;17:70. PMID: 27267887. 10.1186/s12875-016-0461-8 27267887
282 Delaney KE, Lee AK, Lapham GT, . Inconsistencies between alcohol screening results based on AUDIT-C scores and reported drinking on the AUDIT-C questions: prevalence in two US national samples. Addict Sci Clin Pract. 2014;9:2. PMID: 24468406. 10.1186/1940-0640-9-2 24468406
283 D’Amico EJ, Miles JN, Stern SA, . Brief motivational interviewing for teens at risk of substance use consequences: a randomized pilot study in a primary care clinic. J Subst Abuse Treat. 2008;35(1):53–61. PMID: 18037603. 10.1016/j.jsat.2007.08.008 18037603
284 Babor TF, Steinberg K, Anton R, . Talk is cheap: Measuring drinking outcomes in clinical trials. J Stud Alcohol Drugs. 2000;61(1):55–63. PMID: 10627097. 10.15288/jsa.2000.61.55 10627097
285 Del Boca FK, Noll JA. Truth or consequences: The validity of self-report data in health services research on addictions. Addiction. 2000;95(Suppl 3):S347–S60. PMID: 11132362. 10.1080/09652140020004278 11132362
286 Del Boca FK, Darkes J. The validity of self-reports of alcohol consumption: state of the science and challenges for research. Addiction. 2003;98: Suppl 2:1–12. PMID: 14984237. 10.1046/j.1359-6357.2003.00586.x 14984237
287 Patrick ME, Lee CM. Comparing numbers of drinks: college students’ reports from retrospective summary, followback, and prospective daily diary measures. J Stud Alcohol Drugs. 2010;71(4):554–61. PMID: 20553664. 10.15288/jsad.2010.71.554 20553664
288 Northcote J, Livingston M. Accuracy of self-reported drinking: observational verification of ‘last occasion’ drink estimates of young adults. Alcohol Alcohol. 2011;46(6):709–13. PMID: 21949190. 10.1093/alcalc/agr138 21949190
289 Sobell LC, Sobell MB. Timeline follow-back: A technique for assessing self-reported alcohol consumption. 1992. https://pubs.niaaa.nih.gov/publications/assessingalcohol/instrumentpdfs/13_tlfb.pdf.
290 Ridout B, Campbell A. Using Facebook to deliver a social norm intervention to reduce problem drinking at university. Drug Alcohol Rev. 2014;33(6):667–73. PMID: 24689339. 10.1111/dar.12141 24689339
291 American Society of Addiction Medicine. Terminology Related to the Spectrum of Unhealthy Substance Use. Chevy Chase, MD. 2013. http://www.asam.org/docs/default-source/public-policy-statements/1-terminology-spectrum-sud-7-13.pdf?sfvrsn=2.
292 Whitlock EP, Polen MR, Green CA, . Behavioral counseling interventions in primary care to reduce risky/harmful alcohol use by adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140(7):557–68. PMID: 15068985. 10.7326/0003-4819-140-7-200404060-00017 15068985
293 US Department of Health and Human Services; US Department of Agriculture. Dietary Guidelines for Americans 2015-2020. https://health.gov/dietaryguidelines/2015/guidelines/appendix-9/. Accessed August 9, 2016.
294 Centers for Disease Control and Prevention. Fact Sheets - Alcohol Use and Your Health. https://www.cdc.gov/alcohol/fact-sheets/alcohol-use.htm. Accessed July, 2018.
295 World Health Organization. Lexicon of Alcohol and Drug Terms. http://passthrough.fw-notify.net/download/554013/http://apps.who.int/iris/bitstream/10665/39461/1/9241544686_eng.pdf. Accessed August 9, 2016.
296 Isaac M, Janca A, Sartorius N. ICD-10 Symptom Glossary for Mental Disorders. Geneva: World Health Organization; 1994.
297 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition (DSM-5). Arlington, VA: American Psychiatric Association; 2013.
298 Substance Abuse and Mental Health Services Administration. Substance Use Disorders. http://www.samhsa.gov/disorders/substance-use. Accessed August 9, 2016.
299 World Health Organization. The ICD-10 Classification of Mental and Behavioural Disorders http://www.who.int/classifications/icd/en/bluebook.pdf. Accessed Mar 8, 2018.
300 Whiting P, Rutjes AW, Reitsma JB, . The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. PMID: 14606960. 10.1186/1471-2288-3-25 14606960
301 Whiting P, Wolff R. “Medical use of cannabinoids”: In reply. JAMA. 2015;314(16):1751–2. PMID: 26505604. 10.1001/jama.2015.11447 26505604
302 Gmel G, Gutjahr E, Rehm J. How stable is the risk curve between alcohol and all-cause mortality and what factors influence the shape? A precision-weighted hierarchical meta-analysis. Eur J Epidemiol. 2003;18(7):631–42. PMID: 12952136.12952136
303 Knott CS, Coombs N, Stamatakis E, . All cause mortality and the case for age specific alcohol consumption guidelines: pooled analyses of up to 10 population based cohorts. BMJ. 2015;350:h384. PMID: 25670624. 10.1136/bmj.h384 25670624
304 Baliunas DO, Taylor BJ, Irving H, . Alcohol as a risk factor for type 2 diabetes: A systematic review and meta-analysis. Diabetes Care. 2009;32(11):2123–32. PMID: 19875607. 10.2337/dc09-0227 19875607
305 Carlsson S, Hammar N, Grill V. Alcohol consumption and type 2 diabetes Meta-analysis of epidemiological studies indicates a U-shaped relationship. Diabetologia. 2005;48(6):1051–4. PMID: 15864527. 10.1007/s00125-005-1768-5 15864527
306 Koppes LL, Dekker JM, Hendriks HF, . Moderate alcohol consumption lowers the risk of type 2 diabetes: a meta-analysis of prospective observational studies. Diabetes Care. 2005;28(3):719–25. PMID: 15735217. 10.2337/diacare.28.3.719 15735217
307 Reynolds K, Lewis B, Nolen JD, . Alcohol consumption and risk of stroke: a meta-analysis. JAMA. 2003;289(5):579–88. PMID: 12578491. 10.1001/jama.289.5.579 12578491
308 IARC Working Group on the Evaluation of Carcinogenic Risk to Humans. Alcohol Consumption and Ethyl Carbamate. In: IARC Monographs on the Evaluation of Carcinogenic Risks to Humans, No. 96. Lyon (FR): International Agency for Research on Cancer. 2010.
309 Altieri A, Garavello W, Bosetti C, . Alcohol consumption and risk of laryngeal cancer. Oral Oncol. 2005;41(10):956–65. PMID: 15927525. 10.1016/j.oraloncology.2005.02.004 15927525
310 Cho E, Smith-Warner SA, Ritz J, . Alcohol intake and colorectal cancer: a pooled analysis of 8 cohort studies. Ann Intern Med. 2004;140(8):603–13. PMID: 15096331. 10.7326/0003-4819-140-8-200404200-00007 15096331
311 Hamajima N, Hirose K, Tajima K, . Alcohol, tobacco and breast cancer-collaborative reanalysis of individual data from 53 epidemiological studies, including 58,515 women with breast cancer and 95,067 women without the disease. Br J Cancer. 2002;87(11):1234–45. PMID: 12439712. 10.1038/sj.bjc.6600596 12439712
312 Cao Y, Willett WC, Rimm EB, . Light to moderate intake of alcohol, drinking patterns, and risk of cancer: results from two prospective US cohort studies. BMJ. 2015;351:h4238. PMID: 26286216. 10.1136/bmj.h4238 26286216
313 Bagnardi V, Rota M, Botteri E, . Light alcohol drinking and cancer: a meta-analysis. Ann Oncol. 2013;24(2):301–8. PMID: 22910838. 10.1093/annonc/mds337 22910838
314 Henderson J, Kesmodel U, Gray R. Systematic review of the fetal effects of prenatal binge-drinking. J Epidemiol Community Health. 2007;61(12):1069–73. PMID: 18000129. 10.1136/jech.2006.054213 18000129
315 Sokol RJ, Delaney-Black V, Nordstrom B. Fetal alcohol spectrum disorder. JAMA. 2003;290(22):2996–9. PMID: 14665662. 10.1001/jama.290.22.2996 14665662
316 Schuchat A. The CDC’s Recommendations to Help Prevent Fetal Alcohol Spectrum Disorders. Am Fam Physician. 2017;95(1):6–7. PMID: 28075101.28075101
317 Patra J, Bakker R, Irving H, . Dose-response relationship between alcohol consumption before and during pregnancy and the risks of low birthweight, preterm birth and small for gestational age (SGA)-a systematic review and meta-analyses. Bjog. 2011;118(12):1411–21. PMID: 21729235. 10.1111/j.1471-0528.2011.03050.x 21729235
318 Mamluk L, Edwards HB, Savovic J, . Low alcohol consumption and pregnancy and childhood outcomes: time to change guidelines indicating apparently ‘safe’ levels of alcohol during pregnancy? A systematic review and meta-analyses. BMJ Open. 2017;7(7):e015410. PMID: 28775124. 10.1136/bmjopen-2016-015410 28775124
319 O’Keeffe LM, Greene RA, Kearney PM. The effect of moderate gestational alcohol consumption during pregnancy on speech and language outcomes in children: a systematic review. Syst Rev. 2014;3:1. PMID: 24383422. 10.1186/2046-4053-3-1 24383422
320 Henderson J, Gray R, Brocklehurst P. Systematic review of effects of low-moderate prenatal alcohol exposure on pregnancy outcome. Bjog. 2007;114(3):243–52. PMID: 17233797. 10.1111/j.1471-0528.2006.01163.x 17233797
321 Gray R, Mukherjee RA, Rutter M. Alcohol consumption during pregnancy and its effects on neurodevelopment: what is known and what remains uncertain. Addiction. 2009;104(8):1270–3. PMID: 19215606. 10.1111/j.1360-0443.2008.02441.x 19215606
322 Todorow M, Moore TE, Koren G. Investigating the effects of low to moderate levels of prenatal alcohol exposure on child behaviour: a critical review. J Popul Ther Clin Pharmacol. 2010;17(2):e323–30. PMID: 20962358.20962358
323 Kaplan MS, Huguet N, McFarland BH, . Use of alcohol before suicide in the United States. Ann Epidemiol. 2014;24(8):588–92e1-2. PMID: 24953567. 10.1016/j.annepidem.2014.05.008 24953567
324 Cherpitel CJ, Ye Y, Bond J, . Alcohol Attributable Fraction for Injury Morbidity from the Dose-Response Relationship of Acute Alcohol Consumption: Emergency Department Data from 18 Countries. Addiction. 2015;110(11):1724–32. PMID: 26119350. 10.1111/add.13031 26119350
325 Taylor B, Irving HM, Kanteres F, . The more you drink, the harder you fall: a systematic review and meta-analysis of how acute alcohol consumption and injury or collision risk increase together. Drug Alcohol Depend. 2010;110(1-2):108–16. PMID: 20236774. 10.1016/j.drugalcdep.2010.02.011 20236774
326 Eckardt MJ, File SE, Gessa GL, . Effects of moderate alcohol consumption on the central nervous system. Alcohol Clin Exp Res. 1998;22(5):998–1040. PMID: 9726269. 10.1111/j.1530-0277.1998.tb03695.x 9726269
327 Taylor B, Rehm J. The relationship between alcohol consumption and fatal motor vehicle injury: high risk at low alcohol levels. Alcohol Clin Exp Res. 2012;36(10):1827–34. PMID: 22563862. 10.1111/j.1530-0277.2012.01785.x 22563862
328 Peck RC, Gebers MA, Voas RB, . The relationship between blood alcohol concentration (BAC), age, and crash risk. J Safety Res. 2008;39(3):311–9. PMID: 18571573. 10.1016/j.jsr.2008.02.030 18571573
329 Centers for Disease Control and Prevention. Alcohol-attributable deaths and years of potential life lost among American Indians and Alaska Natives-United States, 2001-2005. MMWR Morb Mortal Wkly Rep. 2008;57(34):938–41. PMID: 18756193.18756193
330 Rehm J, Mathers C, Popova S, . Global burden of disease and injury and economic cost attributable to alcohol use and alcohol-use disorders. Lancet. 2009;373(9682):2223–33. PMID: 19560604. 10.1016/S0140-6736(09)60746-7 19560604
331 Stockwell T, Zhao J, Panwar S, . Do “Moderate” Drinkers Have Reduced Mortality Risk? A Systematic Review and Meta-Analysis of Alcohol Consumption and All-Cause Mortality. J Stud Alcohol Drugs. 2016;77(2):185–98. PMID: 26997174. 10.15288/jsad.2016.77.185 26997174
332 Taylor B, Irving HM, Baliunas D, . Alcohol and hypertension: gender differences in dose-response relationships determined through systematic review and meta-analysis. Addiction. 2009;104(12):1981–90. PMID: 19804464. 10.1111/j.1360-0443.2009.02694.x 19804464
333 Chen L, Smith GD, Harbord RM, . Alcohol intake and blood pressure: a systematic review implementing a Mendelian randomization approach. PLoS Med. 2008;5(3):e52. PMID: 18318597. 10.1371/journal.pmed.0050052 18318597
334 Roerecke M, Kaczorowski J, Tobe SW, . The effect of a reduction in alcohol consumption on blood pressure: a systematic review and meta-analysis. The Lancet Public Health. 2017;2(2):e108–e20. PMID: None. 10.1016/S2468-2667(17)30003-8 29253389
335 Xin X, He J, Frontini MG, . Effects of alcohol reduction on blood pressure: a meta-analysis of randomized controlled trials. Hypertension. 2001;38(5):1112–7. PMID: 11711507. 10.1161/hy1101.093424 11711507
336 Ronksley PE, Brien SE, Turner BJ, . Association of alcohol consumption with selected cardiovascular disease outcomes: a systematic review and meta-analysis. BMJ. 2011;342:d671. PMID: 21343207. 10.1136/bmj.d671 21343207
337 Rehm J, Baliunas D, Borges GL, . The relation between different dimensions of alcohol consumption and burden of disease: an overview. Addiction. 2010;105(5):817–43. PMID: 20331573. 10.1111/j.1360-0443.2010.02899.x 20331573
338 Roerecke M, Rehm J. Alcohol consumption, drinking patterns, and ischemic heart disease: a narrative review of meta-analyses and a systematic review and meta-analysis of the impact of heavy drinking occasions on risk for moderate drinkers. BMC Med. 2014;12:182. PMID: 25567363. 10.1186/s12916-014-0182-6 25567363
339 Peters R, Peters J, Warner J, . Alcohol, dementia and cognitive decline in the elderly: a systematic review. Age Ageing. 2008;37(5):505–12. PMID: 18487267. 10.1093/ageing/afn095 18487267
340 Anstey KJ, Mack HA, Cherbuin N. Alcohol consumption as a risk factor for dementia and cognitive decline: meta-analysis of prospective studies. Am J Geriatr Psychiatry. 2009;17(7):542–55. PMID: 19546653. 10.1097/JGP.0b013e3181a2fd07 19546653
341 Andréasson S, Chikritzhs T, Dangardt F, . Evidence about health effects of “moderate” alcohol consumption: reasons for skepticism and public health implications. Stockholm: IOGT-NTO & Swedish Society of Medicine; 2014.
342 Committee on Substance Abuse, Levy S, Kokotailo P. Substance Use Screening, Brief Intervention, and Referral to Treatment for Pediatricians. Pediatrics. 2011;128(5):e1330–e40. PMID: 22042818. 10.1542/peds.2011-1754 22042818
343 American Academy of Pediatrics: Committee on Substance Abuse. Alcohol use and abuse: a pediatric concern. Pediatrics. 2001;108(1):185–9. PMID: 11433075. 10.1542/peds.108.1.185 11433075
344 National Institute for Health and Clinical Excellence (NICE). Alcohol-use disorders. Diagnosis, assessment and management of harmful drinking and alcohol dependence. 2011;115.