# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Ernest Sullivent, MD, MPH, and Amanda Borsky, DrPH, MPP, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Richard Saitz, MD, MPH, at Boston University Schools of Medicine and Public Health, for his content expertise and review of the draft report; Meghan Soulsby Weyrich, MPH, at the University of California, Davis, Center for Healthcare Policy and Research, for her assistance in data abstraction; and Smyth Lai, MLS, and Katherine Essick, BS, at the Kaiser Permanente Center for Health Research, for technical and editorial assistance.