# Chapter 4 Discussion

Unhealthy alcohol use has substantial and wide-ranging negative effects at the individual, family, and societal level. A summary of our findings is presented in Table 12, including our assessment of the overall strength of evidence for each KQ.

Table 12 Summary of Evidence Table

Key question | No. of Studies (k), no. of Observations (n) | Summary of findings | Consistency/precision | Reporting bias | Overall study quality | Body of evidence limitations | EPC assessment of overall strength of evidence | Applicability
KQ1. Benefits of screening | k=0 | NA | NA | NA | NA | NA | Insufficient | NA
KQ2. Screening accuracy | k= 45 n=277,938 | For adolescents, data supported the use of the NIAAA Youth Screen and other one- or two-item screeners to detect AUD; however, data were insufficient to determine whether brief (1- to 3-item) screeners or AUDIT can detect unhealthy use. Preliminary evidence suggests lower cutoffs than the standard ≥8 would be preferred for AUDIT if used. For adults, brief (1- to 3- item) screeners commonly reported sensitivity and specificity between 0.70 and 0.85, typically having better sensitivity than the full AUDIT for identifying the full spectrum of unhealthy use. However, AUDIT tended to have higher specificity, particularly at the standard cutoff of ≥8. Evidence supports the use of brief instruments as initial screeners, where high sensitivity and lower specificity would be desirable, followed by a longer instrument, such as AUDIT, with greater specificity. | Reasonably consistent, reasonably precise (Adolescents, to detect AUD) NA (Adolescents, to predict unhealthy use) Reasonably consistent, reasonably precise (Adults) | None suspected | Good: 17 Fair: 28 | Information around the administration of the screening test and reference standard often not well reported (order of tests, blinding of interviewer to the results of the index test while administering the reference standard). | Moderate (Adolescents, to detect AUD) Insufficient (Adolescents, to detect full spectrum of unhealthy alcohol use) High (Adults) | Many in U.S. primary care, including studies covering both general populations and targeted subgroup with comorbidities and in different types of settings (e.g., including the VA and Indian Health Service). U.S.-based studies outside of primary care included epidemiologic surveys with sampling representative of the U.S. population, with oversampling of racial/ethnic minorities in some cases. Young adult studies primarily in college settings.
KQ3. Harms of screening | k=0 | NA | NA | NA | NA | NA | Insufficient | NA
KQ4a. Benefits of interventions: alcohol use and other risky behavior | k=68 RCTs n=36,528 | Interventions reduced drinks/week (WMD, −1.59 [95% CI, −2.15 to −1.03]), the proportion exceeding recommended drinking limits (OR, 0.60 [95% CI, 0.53 to 0.67]), and the proportion reporting a heavy use episode (OR, 0.67 [95% CI, 0.58 to 0.77]), and increased the proportion of pregnant women reporting abstinence (OR, 2.26 [95% CI, 1.43 to 3.56]). Outcomes were generally reported at 6- to 12-month followup, or during the late pregnancy or early postpartum period for abstinence during pregnancy. Benefits remained through 24 months or beyond in 4 of 7 trials with longer-term outcomes. Heterogeneity was high and effect size was associated with a number of study (but not intervention) characteristics. Reduction in self-reported drinking after driving in 2 of 3 trials. Only 2 trials included adolescents. | Inconsistent and imprecise for adolescents Reasonably consistent, reasonably precise for adults | Suspected, due to detected small-study bias | Good: 10 Fair: 58 | Inconsistency of outcomes reported, and some important outcomes sparely reported, such as proportion meeting or exceeding recommended drinking limits; risk of social desirability bias | Low (Adolescents) Moderate (Adults) | Majority of trials conducted in U.S., in primary care, and in the past 10 years, with representation from a wide range of important subpopulations (e.g., young adults, older adults, pregnant and postpartum women, low income, with comorbidities, racial/ethnic minorities)
KQ4b. Benefits of interventions: health, social, and legal outcomes | k=41 n=20,324 | No evidence in adolescents. In adults, studies reported statistically nonsignificant reduction in all-cause mortality (OR, 0.64 [95% CI, 0.34 to 1.19]), but were underpowered, usually had unclear ascertainment methods, and likely overestimated effect, since many trials not reporting all-cause mortality likely had no deaths. Reductions in ED visits, controlled substance or liquor violations at 4-year followup in 1 good-quality study. Small reduction in alcohol-related consequences in trials of young adults (SMD, −0.06 [95% CI, −0.11 to −0.01]). Other health outcomes sparsely reported, usually not statistically significant, and did not consistently favor the intervention group. 1 trial in pregnant women found higher birth weight among those in the intervention group, but other pregnancy and birth outcomes showed no between-group differences. | Mortality, alcohol-related consequences: Reasonably consistent, imprecise (Adults) Other outcomes: Inconsistent, imprecise (Adults) | Possible for mortality, since all studies reporting had at least 1 death. | Good: 6 Fair: 35 | Wide range of outcomes reported with little replication and few studies reporting any particular outcome; mortality underpowered with ascertainment usually not described | Insufficient (Adolescents) Low (Adults) | Majority of trials conducted in U.S., in primary care, and in the past 10 years, with representation from a wide range of important subpopulations (e.g., young adults, older adults, pregnant and postpartum women, low income, with comorbidities, racial/ethnic minorities)
KQ5. Harms of interventions | k=6 RCTs n=3650 | All trials reporting on adverse effects had 0 adverse effects in both groups. Across all included studies, no pattern of paradoxical effects suggesting risk of harm | Reasonably consistent, imprecise | None detected | Good: 1 Fair: 5 | Sparsely reported | Low | Majority of trials conducted in U.S., in primary care, and in the past 10 years.

Abbreviations: EPC = evidence-based practice center; k = number of studies; KQ = key question; n = number of participants; NA = not applicable; No. = number; OR = odds ratio; RCT = randomized controlled trial; U.S. = United States; WMD = weighted mean difference.

## Summary of Evidence

We found no direct evidence that screening programs reduce unhealthy alcohol use or improve health, compared with usual care (without screening). Multiple screening instruments are available that can detect unhealthy alcohol use with reasonable accuracy, and that require 1 or 2 minutes to administer. For example, studies of adults found that the NIAAA-recommended single question (“How many times in the past year have you had 5/4 [males/females] or more drinks in a day?”) had sensitivity ranging from 0.73 to 0.88 and specificity from 0.74 to 1.0 for detecting unhealthy alcohol use. For the AUDIT-C, sensitivity was similar, but the range of reported specificity was wider. For the full AUDIT, range of sensitivity was wide (0.38 to 0.73) using the recommended cutoff of 8 or higher, but specificity was high (0.89 to 0.97). This pattern supports the use of a brief screener to identify excess use followed by assessment with a more detailed instrument with greater specificity (e.g., the AUDIT), as is currently done in some health care systems,^251–253^ such as the Veterans Health Administration. If used as an initial screening test, data for the AUDIT from U.S.-based primary care settings suggest that lower cutoffs may be preferable (e.g., 3, 4, or 5) to provide a more optimal balance of sensitivity and specificity for detecting the full spectrum of unhealthy alcohol use. Given the low cost of followup questions after a positive screen to confirm the presence of unhealthy alcohol use and determine its extent (if present), clinicians may prioritize sensitivity over specificity, and may consider calibrating the optimal cutoff for their setting. Use of the USAUDIT and USAUDIT-C, designed to use the U.S. standard drink size and to return results consistent with NIAAA recommendations, may improve upon the performance of the standard AUDIT and AUDIT-C.^254^ No studies on the USAUDIT or USAUDIT-C were published during our search window; however, a newly published study in college students confirms that the performance characteristics are at least comparable to the AUDIT and AUDIT-C for determining whether a person exceeds the NIAAA recommended drinking limits.^255^

For adolescents, limited data were available on accuracy of any screening instrument for detecting the full spectrum of unhealthy alcohol use (one study with 225 participants), but multiple studies demonstrated good accuracy of one- or two-item questions and the AUDIT for detecting AUD. Despite the adequate test accuracy, the low prevalence of unhealthy alcohol use among adolescents, older adults, and pregnant women will result in low positive predictive values, less than 50 percent for all scenarios we modeled in these populations (Table 13). Among nonpregnant adults, the prevalence of unhealthy alcohol use is higher, resulting in fewer false positives. For example, the positive predictive value in general adult populations is estimated at 74 percent for identifying persons with heavy use episodes, at a sensitivity of 0.80 and specificity of 0.90.

Table 13 Positive and Negative Predictive Values for a Range of Sensitivity and Specificity Based on U.S. Prevalence of Unhealthy Alcohol Use^11^

Target population | Condition | Condition, % | PPV 70/80^*^ | PPV 80/90^*^ | PPV 90/90^*^ | NPV 70/80^*^ | NPV 80/90^*^ | NPV 90/90^*^
Adolescents | Heavy use episode, past month | 4.9 | 15.3 | 29.2 | 31.7 | 98.1 | 98.9 | 99.4
Adolescents | Heavy drinking, past month | 0.8 | 2.7 | 6.1 | 6.8 | 99.7 | 99.8 | 99.9
Adolescents | AUD, current | 2.0 | 6.7 | 14.0 | 15.5 | 99.2 | 99.5 | 99.8
Adults (18+ years) | Heavy use episode, past month | 26.2 | 55.4 | 74.0 | 76.2 | 88.2 | 92.7 | 96.2
Adults (18+ years) | Heavy drinking, past month | 6.6 | 19.8 | 36.1 | 38.9 | 97.4 | 98.4 | 99.2
Adults (18+ years) | AUD, current | 6.0 | 18.3 | 33.8 | 36.5 | 97.7 | 98.6 | 99.3
Young adult (18-25 years) | Heavy use episode, past month | 38.4 | 68.6 | 83.3 | 84.9 | 81.0 | 87.8 | 93.5
Young adult (18-25 years) | Heavy drinking, past month | 10.1 | 28.2 | 47.3 | 50.3 | 96.0 | 97.6 | 98.8
Young adult (18-25 years) | AUD, current | 10.7 | 29.5 | 48.9 | 51.9 | 95.7 | 97.4 | 98.7
Middle adults (26+ years) | Heavy use episode, past month | 24.2 | 52.8 | 71.9 | 74.2 | 89.3 | 93.4 | 96.6
Middle adults (26+ years) | Heavy drinking, past month | 6.0 | 18.3 | 33.8 | 36.5 | 97.7 | 98.6 | 99.3
Middle adults (26+ years) | AUD, current | 5.2 | 16.1 | 30.5 | 33.1 | 98.0 | 98.8 | 99.4
Older adults (65+ years) | Heavy use episode, past month | 9.7 | 27.3 | 46.2 | 49.2 | 96.1 | 97.7 | 98.8
Older adults (65+ years) | Heavy drinking, past month | 2.3 | 7.6 | 15.8 | 17.5 | 99.1 | 99.5 | 99.7
Older adults (65+ years) | AUD, current | 1.6 | 5.4 | 11.5 | 12.8 | 99.4 | 99.6 | 99.8
Pregnant women | Heavy use episode, past month | 4.3 | 13.6 | 26.4 | 28.8 | 98.3 | 99.0 | 99.5
Pregnant women | Heavy drinking, past month | 0.9 | 3.1 | 6.8 | 7.6 | 99.7 | 99.8 | 99.9
Pregnant women | AUD, current | ^†^ | NA | NA | NA | NA | NA | NA

* Sensitivity/Specificity.

† Data not available.

Abbreviations: AUD = alcohol use disorder; NA = not applicable; NPV = negative predictive value; PPV = positive predictive value.

Our results indicated that among adults who were identified through screening, counseling interventions to reduce unhealthy alcohol use led to reductions in alcohol use (by an average of 1.6 drinks/week), and reduced both the odds of exceeding recommended drinking limits (by 40%) and heavy use episodes (by 33%) at 6 to 12 months of followup (Table 12). Based on these findings, among adults engaged in unhealthy alcohol use, and assuming a control rate of 33 percent drinking within recommended limits at followup (the median of our included trials), such interventions would result in an absolute increase of 14 percent more participants drinking within recommended limits, meaning seven adults would need to be treated to get one drinking within recommended limits (number needed to treat [NNT], 7.2 [95% CI, 6.2 to 11.5]). For context, NNT with high-intensity counseling interventions to prevent one case of a biologically-confirmed sexually transmitted infection ranges from 16 to 69, across three levels of baseline risk. In pregnant women, interventions doubled the odds that women remain abstinent from alcohol during pregnancy (NNT, 6.0 [95% CI, 4.3 to 12.5], assuming a baseline rate of 62% of women being abstinent from alcohol). Intervention effects are likely similar for men and women, and there was no evidence to suggest that different race/ethnicity or socioeconomic subpopulations had lower likelihood of benefit. Evidence in adolescents was limited to two trials, with mixed results.

Very limited data suggested that benefits from alcohol use interventions can be maintained over 2 to 4 years, including both in number of drinks per week and some health outcomes. However, several trials in younger adults found that beneficial effects appeared at 6 months, but were attenuated and no longer statistically significant at 12 months, suggesting that beneficial effects may deteriorate more quickly in younger adults.

While many trials reported health, social, legal, and related outcomes, no specific outcomes were widely reported. Eight trials reported mortality, finding that the interventions were associated with a 36 percent reduction in the odds of death (OR, 0.64 [95% CI, 0.34 to 1.19]), but results were not statistically significant. We found very limited information on harms of the included intervention, but the fact that most results favored the intervention groups across a wide range of outcomes, even though differences were not always statistically significant, suggests very low risk of harm. Several studies reported on the acceptability of the interventions to the participants, and generally reported positive to very positive ratings.^186,^ ^212,^ ^217,^ ^223,^ ^235^

## Comparison With the 2012 USPSTF Review

The previous USPSTF review examined existing systematic reviews to address the question of screening test performance. The previous reviewers concluded that a single-question screener, the AUDIT-C, and the AUDIT appeared to be the best overall instruments for screening adults for the full spectrum of unhealthy alcohol use in primary care, with single-question screeners having reported sensitivity of 0.82 to 0.87 and specificity of 0.61 to 0.79. They further concluded that lower cut-points on the AUDIT than the standard 8 or higher may provide a more optimal balance of sensitivity and specificity in U.S.-based primary care. We examined original studies rather than existing systematic reviews, so our evidence base is more directly applicable to U.S. primary care, and at least 60 percent of the studies included in our review were published after the search windows of the previous review’s evidence, so most of the included studies are new since the previous review. The ranges of sensitivity and specificity estimated by the previous review for adults are solidly in the range of the sensitivity and specificity seen in our review in studies of adults. Among the newly included evidence is 10 studies in adolescents, who were not previously represented.

Among intervention trials included in our review, the pooled effect size was more than two drinks per week larger for trials that were included in the previous review^83^ than for trials that were not included in the previous review (Figure 15). Table 14 shows intervention trial results from the previous and current reviews side-by-side. While reductions in drinks per week were larger in the previous review, other drinking outcomes showed very similar results. One of the main differences between the two reviews is the inclusion of studies conducted outside of primary care settings in the current review, which resulted in the inclusion of a substantial number of studies in college settings. Differences in the results for drinks per week between the two reviews were likely due to this and other factors, including differences in the distribution of population age and severity, and possibly also to small-study effects or secular trends in treatment response over time. Differences between reviews in drinks per week were less pronounced within the general and older adult trials. For example, the average relative reduction in drinks per week in general adult populations was 3.6 in the previous review and 2.5 in the current review. Our estimated absolute increase of 14 percent more participants drinking within recommended limits based on the assumption described in the previous paragraph (and NNT of 7.2) is also consistent with the 11 percent increase (NNT, 9) reported in the previous review. Also consistent with the previous review was our finding of a fairly large but statistically nonsignificant association between interventions and reduced all-cause mortality, with a 36 percent reduction in the odds of death in the current review (OR, 0.64 [95% CI, 0.34 to 1.19]), compared with a 48 percent reduction in the risk of death in the previous review (RR, 0.52 [95% CI, 0.22 to 1.22]).

Table 14 Comparison With the 2012 USPSTF Review: Differences in Change in Alcohol Outcomes Between Alcohol Counseling Intervention Groups and Control Groups

Target population | Outcome | Current review | 2012 review
General adult populations | Drinks/week | −2.51 (95% CI, −3.81 to −1.21) | −3.6 (95% CI, −4.8 to −2.4)
General adult populations | % Within recommended limits^*^,^†^ | RD, 14% (95% CI, 9% to 16%) | RD, 11% (95% CI, 8% to 13%)
General adult populations | % Heavy use episode^‡^ | RD, -10% (95% CI, -14% to -5%) | RD, -12% (95% CI, -16% to -7%)
Older adults | Drinks/week | −2.98 (95% CI, −6.96 to 0.99) | −1.7 (95% CI, −2.8 to −0.6)
Older adults | % Within recommended limits^*^,^†^ | RD, 13% (95% CI, 5% to 20%) | RD, 9% (95% CI, 2% to 16%)
Older adults | % Heavy use episode^‡^ | RD, -10% (95% CI, -14% to -5%) | Not available
Younger adults | Drinks/week | −0.86 (95% CI, −1.29 to −0.43) | −1.7 (95% CI, −0.07 to −2.6)
Younger adults | Heavy use episodes/month | −0.2 (95% CI, −0.6 to 0.2) | −0.9 (95% CI, −0.3 to −1.5)
Pregnant women | Drinks/week | No difference (2 studies) | No difference (1 study)
Pregnant women | Abstinence | OR, 2.26 (95% CI, 1.43 to 3.56) | Greater abstinence in subgroup only of 1 study
Adolescents | Drinks/week; drinking days in past month | Mixed results (2 studies) | No evidence

* The outcome exceeding recommended limits was flipped to reflect within recommended limits, for consistency with the previous review.

† The assumed control group percent within recommended limits was 33% for general adult populations, 56% for older adult populations.

‡ The assumed control group percent with a heavy use episode was 39% for general adult populations, 31% for older adult populations.

Abbreviations: RD = risk difference; USPSTF = United States Preventive Services Task Force.

## Comparison With Other Reviews

We found only one systematic review of test performance of a relevant screening tool that was published after the previous review, which confirmed the efficiency of the English-language AUDIT, AUDIT-C, and other abbreviated versions of the AUDIT, as well as other language-adapted versions.^256^ Other systematic reviews of interventions to reduce unhealthy alcohol use are largely consistent with our findings. For example, a series of systematic reviews of experimental and quasiexperimental studies in adolescents and young adults^257–259^ found relatively small but statistically significant effects in young adults (e.g., an estimated 0.8 fewer drinking days per month) that weakened with longer-term followup. A separate review in young adults reported a similar standardized effect size, which translated to reducing drinks per week from 13.7 at baseline to 12.5 at followup (standardized mean difference between groups, −0.14 [95% CI, −0.21 to −0.07]).^260^ Systematic reviews of electronic screening and brief interventions among trials targeting all ages also found effect sizes consistent with ours,^261,^ ^262^ such as a greater pooled reduction of 15 g of ethanol per week (WMD, −14.91 [95% CI, −25.56 to −4.26]) in intervention versus control groups after 6 to 11 months, and 7.5 g per week at 12 months (WMD, −7.46 [95% CI, −25.34 to 10.43]).^261^ Using a conversion factor of 14 g of ethanol for one drink, this is similar to the effect found in young adults in our studies of just under one drink per week, measured at 6 to 12 months. While this review included studies from a wide range of countries and settings, five of the eight trials in the meta-analysis of 6- to 11-month outcomes were trials in young adults that were included in our review. Approximately half of the trials in young adults in our review were electronically-based interventions. The other review of electronic interventions found a similar effect size of roughly one drink per week.^262^ We did not find other recent systematic reviews of the benefits or harms of interventions in general adult populations.

## Other Evidence Related to Benefits and Harms of Screening

Although no trials met our inclusion criteria for the KQs related to the benefits and harms of screening compared with no screening, we identified two trials that explored the population-level effect of alcohol screening programs. Control group participants were screened in both trials, so they did not meet the criterion for KQ1 of having an unscreened control group. These trials provided weak evidence for alcohol-use screening programs and suggest this could be a promising area for future research. Both trials screened for a number of risk factors for an outcome of interest (cancer^263^ and alcohol-exposed pregnancy^264^), including unhealthy alcohol use. After screening, patients in the intervention groups were provided with counseling targeted to risk factors identified by the screening. In both trials, results were reported for the full study sample, not only those who screened positive for unhealthy alcohol use. A trial of American Indian/Alaska Native women found a statistically nonsignificant reduction in the proportion at high risk for an alcohol-exposed pregnancy at followup (reduced from 36.4% at baseline to 18.9% in the intervention group, and 33.6% to 22.1% in the control group; p=0.72; n=263).^264^ The other trial, in Spanish primary care patients, found that after 18 months, the proportion meeting criteria for risky drinking fell from 10.1 to 4.9 percent in the intervention group, versus 10.0 to 8.3 percent in the control group (OR, 0.50 [95% CI, 0.35 to 0.72]; p<0.001; n=3,031). Neither study reported on harms. Another study of a screening and motivational interview intervention was excluded due to high attrition (46% lost to followup).^265^ This study in young women (mean age, 18.2 years) presenting at youth health centers did not show group differences in alcohol use outcomes at 12-month followup, among those with high-risk alcohol use at baseline.

## Contextual Information to Bound Intervention Effect Sizes Found in the Current Review

Based primarily on data in nonpregnant adults, we identified several factors that were associated with reduction in number of drinks per week, such as sample size, publication year, baseline alcohol use, target age of the population, setting, and possibly contact time among trials of general and older adults. We were unable to determine which factors were most likely to have causal associations with drinks per week since they tended to cluster together; older studies tended to have smaller sample sizes, target heavier drinkers, have been conducted in primary care, target general adult populations, and have larger effects. Given the relatively larger effects in primary care settings, even if the overall reduction of 1.8 drinks per week is an overestimate due to small-study effects or secular changes in treatment responsiveness, it is likely a reasonably conservative lower-bound estimate of the true, current effect in primary settings, targeting the full spectrum of unhealthy alcohol use. Further, our results could also underestimate the true effect, since the assessment and minimal interventions may have contributed to reduced drinking in control groups. A systematic review concluded that answering questions about drinking in brief intervention trials seems to alter subsequent self-reported behavior, potentially generating bias (toward the null) by exposing nonintervention control groups to an integral component of the intervention.^266^ Indeed, many included trials showed drinks per week declining over time in the control group as well as the intervention group, particularly between baseline and the first followup.

Our results for mortality (OR, 0.64 [95% CI, 0.34 to 1.19]) were consistent with the effect of reduced alcohol use on persons with AUD in a systematic review of 16 studies among individuals with AUD at baseline.^267^ This review found that participants who reduced their drinking but did not attain abstinence had a 39 percent reduction in the odds of death compared with those who continued heavy drinking (OR, 0.61 [95% CI, 0.39 to 0.94]).^267^ This supports the potential clinical importance of our mortality results, although caveats regarding potential reporting bias, lack of information about ascertainment, and imprecision in our evidence remain important.

The most commonly reported health outcome was alcohol-related problems or consequences. This outcome was frequently reported in young adults, typically using the RAPI. This may be an important outcome for young persons, as there is some evidence linking RAPI scores at age 18 years to diagnosis of AUD 7 years later.^268^ This study of twins, who were concordant and discordant for both RAPI score at age 18 years and AUD at age 25 years, found a 10-fold increase in the odds of having a diagnosis per unit increase in the RAPI score at age 18 years. Several of our included studies reported between-group differences in change in the range of 0.4 to 1.5 units on the RAPI,^160,^ ^198,^ ^200,^ ^205,^ ^211^ favoring the intervention group; however, the units varied across studies, hampering interpretation (i.e., some used the RAPI as a 23-point scale, others as a 69-point scale, and other variations). Also, two trials reported similar absolute changes, but favoring the control group.^170,^ ^189^

A few of our trials reported on emergency and inpatient health care utilization,^153,^ ^160,^ ^172,^ ^183^ with mixed results and generally limited power. Among studies that were not included in our review, one uncontrolled implementation study suggests the potential for benefit with large-scale implementation.^269^ This study of Medicaid patients at 33 clinics in Wisconsin found that screening and brief interventions for unhealthy alcohol use in these real-world settings reduced hospital days by 0.036 days per member per month (PMPM), although the effect on inpatient admissions (−0.001 admissions PMPM) and emergency department days (−0.004 days PMPM) were not statistically significant.^269^

## Importance of Specific Intervention Components

Aside from a nearly statistically significant effect of single versus multiple contacts among general and older adults, we did not find intervention characteristics that were clearly associated with drinks per week, in-person versus Web-only contact, or use of motivational techniques, personalized normative feedback, or cognitive behavioral approaches, and other outcomes were too sparely reported to support these exploratory analyses. We did not include comparative effectiveness studies, which may have helped illuminate the importance of components. However, other reviews and pooled analyses that have included comparative effectiveness studies found no association between effect size and a number of specific components or therapist behaviors, with the possible exception of self-monitoring.^270,^ ^271^ An integrative data analysis of individual-level data from 31 brief motivational interventions found that the largest effects were seen for interventions with the highest degree of personalization and breadth of coverage (operationalized as the number of different components addressed). Interestingly, however, when the interventions were minimally personalized, effects were larger when fewer components were addressed than when many components were covered, suggesting a simpler message had more effect when the intervention was not personalized.^272^ Another study found that a stronger therapeutic alliance was associated with greater declines in drinking across multiple therapeutic approaches, which is likely more reflective of interventionist skill than specific change-promoting techniques.^273^ One review of interventions in adolescents and young adults found that motivational interviewing and the use of decisional balance and goal-setting exercises were associated with larger effects in trials of interventions to reduce alcohol use, but this review included both universal and indicated prevention interventions, a wider range of settings, and did not require recruitment through screening, so applicability is somewhat limited.^258^

## Implementation of Interventions to Reduce Unhealthy Alcohol Use

Several large-scale implementation studies have demonstrated that it is feasible to implement screening programs in real-world primary care systems. These studies have found that implementation of screening or SBIRT programs for unhealthy alcohol use substantially increased the odds that patients were screened for unhealthy alcohol use and received appropriate counseling.^274,^ ^275,^ ^276^ Some studies have found that having support staff or embedded behavioral health practitioners conduct screening and interventions improves rates of these services over physician-based screening,^276–278^ and that behavioral health practitioners provided fewer referrals to specialty care (instead providing the counseling themselves), likely because they had more time than pediatricians to address the patients’ alcohol and substance use.^276^ These findings are consistent with those of a recent review of implementation approaches, which concluded that implementation programs should ideally include a combination of patient-, clinician-, and organizational-oriented approaches and involve midlevel health professionals as well as physicians.^279^

A 12-week implementation study found that training and support plus financial reimbursement were associated with increases in screening for unhealthy alcohol use and brief interventions for those screening positive in 120 primary health care units across five European countries. Free access to a Web-based brief intervention tool without training and financial reimbursement did not increase screening or intervention delivery in this study.^280^ This study further found that continuous provision of training and support, sufficient time to learn the intervention techniques, and time to tailor training to individual experienced barriers were rated as important by clinicians.^281^

In terms of intervention contact, many interventions in the trials included in this review were entirely consistent with published guidelines (Table 3), particularly those that were conducted in primary care settings and that involved direct contact with an interventionist. Several trials referred to an NIAAA guide^170,^ ^190,^ ^218^ or the Feedback, Responsibility, Advice, Menu, Empathy, Self-efficacy (FRAMES) framework,^168,^ ^206,^ ^212,^ ^219^ which was explicitly incorporated into the WHO guide. The guides have not specifically incorporated the use of personalized normative feedback; however, it certainly fits under the recommendation to provide feedback on the patient’s drinking level, universal to all of these guides.

## Applicability

One strength of this evidence base is its relatively high applicability to U.S. primary care. Most of the included studies were conducted in primary care settings, in the United States, or both. Although some studies examining test performance had high-risk samples with higher than average rates of unhealthy alcohol use, the percent of unhealthy alcohol users generally ranged from the low 20s to low 30s in adults, which is consistent with the proportion of adults with heavy use episodes in the past month in the United States. The rates of AUD in the test performance studies in adults most commonly ranged from 9 to 11 percent, which is slightly, but not substantially, higher than the 6.0 percent nationwide rate of AUD. Among intervention trials, effect sizes in primary care–based studies and those conducted in the United States were generally comparable or larger than the full body of evidence, and most studies did not have highly restrictive inclusion criteria, suggesting the results of our pooled analyses are likely to hold up in primary care settings. In addition, a wide range of subpopulations were represented in the evidence, including studies targeting racial/ethnic minority patients, different age ranges, males and females, different geographic regions, pregnant and postpartum women, economically disadvantaged populations, veterans, and persons with medical comorbidities.

## Limitations of Our Review

One potential limitation to our approach is that we did not include comparative effectiveness trials, which have the potential to identify important features or mechanisms of change. As discussed above, however, several other studies and reviews have not been able to identify key treatment components or mechanisms of change, even when examining comparative effectiveness studies.

We also did not include evidence regarding use of medication in treatment of AUD. While this is primarily relevant to treatment of more severe disorders rather than screen-detected samples, medication would likely be appropriate for some patients identified through screening.

Among adolescents, we did not include trials addressing prevention of unhealthy alcohol use. This was outside the scope of our review but may be an important body of literature to consider when developing recommendations for adolescents.

Also, our estimate of drinks per week has an extra level of uncertainty due to differences in the size of a standard drink across studies. The most commonly reported definition of a standard drink was 10 g of ethanol/drink, but ranged from 8 to 14 g. We used 14 g as a conversion factor when studies reported grams rather than drinks, for comparability with studies conducted in the United States, which presumably used a conversion factor of 14. An ideal approach would have been to convert drinks per week to grams of ethanol/week; however, data were insufficient to do so. Since some countries do not have published standard drink sizes measured in grams/ethanol, we could not apply conversion factors based only on country in which the study took place.

## Limitations of the Studies and Future Research Needs

We found no trials comparing screening programs with usual care (without universal screening). While these trials are difficult, and some kind of baseline assessment would be needed to understand baseline comparability between groups, it would nevertheless be useful to conduct a study with an unscreened comparison group to understand the population-level effect of screening in primary care settings.

We found no eligible studies that evaluated the versions of the AUDIT and AUDIT-C recently developed for the United States (USAUDIT and USAUDIT-C) that were published during our search window. The USAUDIT/USAUDIT-C is an adaptation of the AUDIT/AUDIT-C to the U.S. standard drink size that modifies the response categories for the quantity/frequency items to allow alignment with NIAAA recommendations. For example, the item asking about heavy use episodes was changed to be five/four or more drinks on one occasion for males/females, from six or more drinks in the original AUDIT/AUDIT-C. Indeed, one study has determined that the AUDIT-C miscategorized up to 21 percent of individuals in the United States due to the mismatch between the response categories and NIAAA-specific recommendations.^282^ Although none of the included studies specifically assessed the USAUDIT relative to a reference standard, it is likely comparable to or better than the AUDIT and AUDIT-C relative to NIAAA-recommended limits. For example, women drinking one drink per day score positive on the original AUDIT-C but are still within NIAAA-recommended levels; these women would not screen positive on the USAUDIT-C. Indeed, in our review, studies assessing one- or two-item screeners that used five/four (males/females) drinks (as in the USAUDIT) tended to report better sensitivity than those using the six-drink standard (as in the original AUDIT), supporting its use in the U.S. population. In addition, one study in college students published after our search window found that the sensitivity was higher for the U.S. versions (AUDIT, 0.68; USAUDIT, 0.72; AUDIT-C, 0.75; USAUDIT-C, 0.87), although specificity was improved only for the full AUDIT/USAUDIT (AUDIT, 0.79; USAUDT, 0.84; AUDIT-C, 0.86; USAUDIT-C, 0.79).^255^ CIs were not provided, so it is unclear if the differences were statistically significant, but these findings suggest that the USAUDIT/USAUDIT-C have at least comparable, and possibly better, test performance than the original version relative to NIAAA standards. Further test performance studies of the USAUDIT and USAUDIT-C are needed to confirm its accuracy in identifying unhealthy alcohol users.

Another limitation of the evidence on the accuracy of screening instruments is that studies sometimes used variations of the standard instruments and cut-points, and the gold standard was also heterogeneous across studies. The definition of “exceeding recommended limits” in studies conducted outside the United States often differed from the U.S. definition of exceeding limits. This likely increased the variability in results. However, the fact that sensitivity and specificity were commonly above 0.70 across a wide range of variations supports the robustness of these tools, even with modifications.

One important limitation of the evidence on the benefits and harms of alcohol interventions is the lack of a consistently reported group of outcomes. The most commonly reported outcome was drinks per week, which was reported in only about two-thirds of the trials in adults. Other important outcomes were reported much less frequently. It would be beneficial for trials to routinely report outcomes with the greatest clinical meaning, such as the proportion of participants with alcohol use within recommended limits, the proportion with heavy use episodes, and health (including alcohol-related medical conditions), social, and legal outcomes. This includes reporting of health care utilization reflecting emergent or serious health effects (e.g., emergency department visits, inpatient stays), and patient-reported health outcomes such as alcohol-related problems or consequences would also be valuable. The TrEAT trial provides an excellent example of using multiple objective sources such as electronic medical records, government crime and transportation databases, as well as self-report.

It would also be useful for trials to plan a priori to report subgroup effects in important subpopulations, such as by age group, sex, race/ethnicity, and baseline severity. It is preferable to test interaction terms, although recognizing that these may be underpowered, reporting of subgroup effects could still be useful, even in the absence of statistically significant interactions.

We found only two trials of interventions to reduce alcohol use in adolescents, even though alcohol use in adolescents is relatively common. The one other trial we found (but excluded due to having only 3 months of followup) did not show positive results but was quite small (n=42), so results could have been limited more by power than by effect size.^283^ In addition, we found one systematic review, which was not included in our evidence base, of experimental and quasiexperimental studies of brief alcohol interventions in any setting. This review identified 24 studies in adolescents.^258^ It found an estimated reduction of 1.3 fewer drinking days per month and an 8-percentile improvement in alcohol-related problems with brief interventions, which is promising in this age group. Almost all of these interventions were conducted in school settings, so how these findings translate to primary care settings is not yet understood. More studies are needed in adolescents outside of school settings, particularly in primary care settings.

Although we found many trials targeting young adults, most of those involved only very brief interventions and had relatively small effects. Given the very high rates of unhealthy alcohol use in young adults, further development of interventions that could have a larger and more long-lasting effect is warranted, such as interventions with more and/or longer contacts and that involve interacting with a person rather than purely computer-based. Additionally, testing some of the computer-based interventions that showed the largest absolute effects in a health care setting would be useful, as these interventions would certainly be feasible for a health system to offer, and could have wide reach.

Data were also limited in older adults, with only four intervention trials. Given that NESARC data show increasing rates of unhealthy alcohol use in older adults and given that the largest effects were seen in the oldest trial (published almost 20 years ago), ensuring that interventions continue to be effective in the current and future generations of older adults is important. In addition, the existing studies had limited racial/ethnic and socioeconomic diversity, so research including these important subpopulations is imperative.

Among general adult populations, areas for future research include more studies exploring features to facilitate dissemination and implementation would be useful. In addition, more studies exploring primary care–based treatment approaches in populations with comorbid medical and mental health conditions that are primary care–based would be useful.

One concern with this literature is the validity of self-report, given that it may be difficult to recall drinking amounts accurately and participants might find it uncomfortable to admit to high levels of alcohol use, particularly after participating in an intervention to reduce their use. Unfortunately, there is no good, widely available, objective measure of alcohol use, so studies necessarily rely on self-report. Some studies have suggested that accurate alcohol use can be collected through self-report, if done carefully,^284,^ ^285^ as it was with many of the included studies. Included trials typically described emphasizing the confidential nature of the data collection, and in many cases used mailed questionnaires or computer-based data collection instruments to minimize demand characteristics. Twelve trials^153,^ ^157,^ ^163,^ ^165,^ ^168,^ ^172,^ ^174,^ ^175,^ ^198,^ ^203,^ ^206,^ ^209^ had participants identify collateral informants who could confirm their alcohol use, which is thought to improve self-report accuracy. In addition, retrospective measures with shorter recall periods (e.g., 1 week, 1 month) tend to have better accuracy that longer recall periods (e.g., 1 year), and most recall periods were 1 to 3 months in the included trials.^286^ Findings also suggest that retrospective recall leads to underestimates of drinking quantity,^287^ particularly when heavy drinking is involved,^288^ yet the included trials employed retrospective strategies. To compensate for this, many trials used the TLFB approach or similar calendar-based methods to estimate daily drinking,^289^ which have better accuracy than general recall items. Most of these limitations would likely apply equally to intervention and control participants, thus limiting precision but not necessarily biasing results. We hypothesized that social desirability bias may be stronger in individuals who have participated in an alcohol reduction intervention but could not find studies that explored this. Careful assessment—such as use of TLFB methods—covering relatively short time periods, with blinded interviewers or neutral data collection methods such as computer-based or mailed questions and strenuous assurances of confidentiality, are important for future studies in this area.

Another important limitation to the body of evidence was the inability to tease out the contribution of several study characteristics to effect size heterogeneity because characteristics tended to clusters together. The field of alcohol research in nondependent users has moved toward lower-intensity interventions, which can be delivered to large numbers of persons more easily. Thus, newer trials generally enrolled more participants, had less restrictive inclusion criteria in terms of alcohol use severity, provided brief interventions, and frequently targeted college-age adults. Continued exploration of effects in primary care settings among adults of all ages, with subgroup analyses among different age groups, would be valuable for understanding the effect of these interventions in current primary care settings.

It would also be useful to see trials that evaluate the effectiveness of brief or electronically-based interventions delivered through other existing public health infrastructure, such as already-existing Web sites or smoking cessation quit lines. For example, one trial in college students delivered a personalized, normative feedback intervention through Facebook and found reductions in drinking 3 months later.^290^ More studies with longer followup utilizing such existing resources would explore the potential to leverage these mechanisms to deliver alcohol use interventions more broadly.

Ongoing studies are reported in Appendix J.

## Conclusion

We found no direct evidence on the effect of screening programs for unhealthy alcohol use. Among adults, screening instruments are available that can accurately identify unhealthy alcohol users that are feasible for use in primary care settings, and interventions in persons who screen positive are associated with reductions in unhealthy alcohol use. Very limited evidence suggests a possible beneficial effect on hospitalizations and substance use violations, but the effect on all-cause mortality is uncertain, and other health outcomes showed no clear benefit. There is no evidence to suggest that these interventions have unintended harmful effects. More evidence is needed to determine whether screening for unhealthy alcohol use is beneficial for adolescents.