# Chapter 3 Results

## Literature Search

We reviewed 17,149 abstracts and 570 full-text articles for all KQs (Appendix A Figure 2), and included 113 studies, reported in 160 publications. The list of included studies and excluded studies (with reasons for exclusion) are available in Appendix E and Appendix F, respectively.

## KQ1a Does Primary Care Screening for Unhealthy Alcohol Use in Adolescents and Adults, Including Pregnant Women, Reduce Alcohol Use or Improve Other Risky Behaviors?

## KQ1b Does Primary Care Screening for Unhealthy Alcohol Use in Adolescents and Adults, Including Pregnant Women, Reduce Morbidity or Mortality or Improve Other Health, Social, or Legal Outcomes?

We found no trials that examined the direct effect of screening for unhealthy alcohol use on alcohol use or on health, social, or legal outcomes.

## KQ2 What Is the Accuracy of Commonly Used Instruments to Screen for Unhealthy Alcohol Use?

### Included Studies

We identified 45 studies^84,^ ^93–136^ (reported in 56 publications^84,^ ^93–147^) (Table 4) that addressed the accuracy of screening instruments (KQ2): 10 in adolescents,^101,^ ^102,^ ^105,^ ^114,^ ^116,^ ^118,^ ^119,^ ^123,^ ^130,^ ^131^ five in young adults,^84,^ ^95,^ ^109,^ ^120,^ ^127^ 27 in general adult populations,^93,^ ^96–99,^ ^103,^ ^104,^ ^106–108,^ ^110–113,^ ^115,^ ^117,^ ^121,^ ^122,^ ^124–126,^ ^128,^ ^129,^ ^132–134,^ ^136^ one in older adults,^94^ and two in pregnant^100^ or postpartum women.^135^ One study in a general adult population provided subgroup analyses of pregnant women and older adults,^106,^ ^139^ and one study of participants ages 12 to 20 years provided subgroup analyses of young adults (ages 18 to 20 years).^102^ The majority of studies were conducted in the United States (28/45 [62%]) and recruited patients from primary care (23/45 [51%]) (Table 5). The number of screened participants ranged from 95 to 166,165. A variety of one- or two-item screening tests were used in the included studies, as well as the AUDIT, AUDIT-C, and ASSIST. The one- or two-item screening tools addressed a variety of specific targets, such as typical or maximum drinks per drinking day (quantity), number of unhealthy drinking days over a specified time period (frequency), or typical total number of drinks over a specific time period (quantity x frequency). Response categories and cutoffs also varied. Studies sometimes assigned a certain number of drinks to be the cutoff (e.g., more than four drinks on one occasion at any time during the time window). Others used questions with Likert-type response categories, such as Item 3 from the AUDIT-C (often referred to as the AUDIT-3), which asks, “How often do you have six or more drinks on one occasion?” and has response categories of 0 (never), 1 (less than monthly), 2 (monthly), 3 (weekly), and 4 (daily or almost daily); for a given study, a positive screening value may be 1, 2, or 3. We accepted minor variations of the named screening tools, such as modified response categories or wording.

Table 4 Study and Population Characteristics for KQ2, by Population

Target population | Author, year | Quality rating | Country | Recruit. setting | Brief population description | N screened | Average age | % Female | Race/Ethnicity | SES | Screening tests
Adolescents | Chung, 2012^101^ | Good | US | Community-based | Adolescents, ages 12-18 years | 166,165 | NR | 48.6 | White: 62.3 Black: 14.7 Hispanic: 16.5 | NR | 5+ drinks Frequency Quantity
Adolescents | Clark, 2016^102^ | Good | US | Primary care | Adolescents, ages 12-20 years, living in rural PA | 1193 | 15.3 | 57 | White: 93.4 Black: 1.3 Hispanic: 4.5 | NR | Frequency Quantity Quant x Freq
Adolescents | D’Amico, 2016^105^ | Good | US | Primary care | Adolescents, ages 12-18 years | 1573 | 15.5 | 57.5 | White: 14.7 Black: 26.7 Hispanic: 51.4 | NR | AUDIT Youth Screen
Adolescents | Gryczynski, 2015^114^ | Fair | US | Primary care | Adolescents, ages 12-17 years | 525 | NR | 54 | White: <1 Black: 93 Hispanic: 3 | 97% enrolled in school | ASSIST
Adolescents | Harris, 2016^116^ | Good | US | Primary care | Adolescents, ages 12-17 years | 136 | 15.0 | 54.4 | White: 18.4 Black: 27.9 Hispanic: 24.3 | 58% college graduate parent | Frequency
Adolescents | Kelly, 2014^118^ | Fair | US | Primary care | Adolescents, ages 12-17 years | 525 | NR | 54.5 | White: 0.8 Black: 92.8 Hispanic: NR | 97.5% enrolled in school | Youth Screen
Adolescents | Knight, 2003^119^ | Good | US | Primary care | Adolescents, ages 14-18 years | 538 | 16 | 68.4 | White: 24.2 Black: 50.6 Hispanic: 18.8 | NR | AUDIT
Adolescents | Levy, 2016^123^ | Fair | US | Other medical | Children, ages 9-18 years, with type 1 diabetes, asthma, cystic fibrosis, inflammatory bowel disease, or juvenile idiopathic arthritis | 388 | NR | 51.5 | White: 75.5 Black: NR Hispanic: NR | 69.8% college graduate parent | Youth Screen
Adolescents | Rumpf, 2013^130^ | Fair | DEU | High School | Adolescents, ages 14-18 years | 225 | 15.5 | 50.7 | NR | NR | AUDIT AUDIT-C
Adolescents | Santis, 2009^131^ | Fair | CHL | High School | Students attending public school | 95 | 15.9 | 44.2 | NR | NR | AUDIT
Young adults | Aertgeerts, 2000 | Fair | BEL | University/College | College freshmen, attending required medical exams | 3564 | 18 | 54.4 | NR | NR | AUDIT
Young adults | Clark, 2016^102^ | Good | US | Primary care | Adolescents, living in rural PA, ages 18-20 years (this subgroup only) | 251 | NR | 66.5 | White: 93.4^*^ Black: 1.3^*^ Hispanic: 4.5^*^ | NR | Frequency, Quantity, Quant x Freq
Young adults | Cook, 2004^84^ | Good | US | Other medical | Young adults attending appointment at an urban STD clinic, ages 15-24 years | 358 | 20.6 | 45.0 | White: 46.0 Black: 49.0 Hispanic: NR | NR | AUDIT
Young adults | DeMartini, 2012^109^ | Good | US | University/College | College students, psychology subject pool, ages 18-25 years, current drinkers | 401 | 19.04 | 54 | White: 64 Black: NR Hispanic: NR | NR | AUDIT, AUDIT-C
Young adults | Kokotailo, 2004^120^ | Good | US | University/College | College students attending university health services appointment, ages 18-23 years | 302 | 20.3 | 61.3 | White: 90.1 Black: 2.0 Hispanic: 2.3 | NR | AUDIT
Young adults | Northrup, 2013^127^ | Fair | US | University/College | White or black non-Hispanic undergraduate college students, ages 18-25 years | 1500 | 19.4 | 68 | White: 81 Black: 19 Hispanic: NR | NR | AUDIT, AUDIT-C
Adults | Aalto, 2009^93^ | Fair | FIN | Other medical | Adults participating in the FINRISK study, ages 25-64 years | 1851 | 45.4 | 54.4 | NR | Education, mean: 13.7 years Employed: 73.7 | AUDIT, AUDIT-C, 6+ drinks, Quantity x Frequency
Adults | Bartoli, 2016^96^ | Good | ITA | Other medical | Adults, age >18 years, admitted to outpatient clinic for anxiety or depressive disorder, with past-year alcohol use | 242 | 44.3 | 57.0 | NR | NR | 5/4+ drinks
Adults | Boschloo, 2010^97^ | Fair | NLD | Community-based | Adults, ages 18-65 years, participated in the Netherlands Study of Depression and Anxiety (NESDA) who had diagnosis of past-year depressive and/or anxiety disorder OR who did not have a diagnosis of lifetime depressive and/or anxiety disorder | 2404 | 41.3 | 65.8 | NR | Education, mean: 12.1 years | AUDIT
Adults | Bradley, 2003^98^ | Good | US | Other medical | Women receiving VA outpatient care, age ≥18 years | 393 | 46 | 100.0 | White: 69.2 Black: 12.2 Hispanic: NR | HS degree or higher: 99.5% | AUDIT, AUDIT-C, 4+ drinks, 6+ drinks
Adults | Buchsbaum, 1995^99^ | Fair | US | Primary care | Adults age ≥18 years, drinking within the past 30 days | 155 | 48 | 44.5 | NR | HS degree or higher: 27.1% Full-time employment: 15.5% Part-time: 10.3% | Quantity
Adults | Clements, 1998^103^ | Fair | US | University/College | College students enrolled in psychology courses, ages 18-55 years | 306 | 25.8 | 74.8 | White: 60.8 Black: 24.5 Hispanic: 10.5 | NR | AUDIT
Adults | Crawford, 2013^104^ | Fair | US | Other medical | Adult veterans from the VA Mid-Atlantic Mental Illness Research, Education, and Clinical Center Recruitment Database | 1775 | 37 | 20.3 | White: 55 Black: NR Hispanic: NR | Education, average: 13 years Employed full- or part-time: 65% | AUDIT, AUDIT-C
Adults | Dawson, 2005^106,^ ^139^ | Good | US | Community-based | Adult participants in the 2001-2002 NESARC, age ≥18 years | 43093 | | | NR | NR | AUDIT-C, 5/4+ drinks Maximum drinks
Adults | Dawson, 2012^107^ | Fair | US | Community-based | Adults, age ≥21 years, participated in NESARC | 34,536 | NR | NR | NR | NR | AUDIT-C
Adults | Degenhardt, 2001^108^ | Fair | AUS | Community-based | Adult participants of WHO trial of brief alcohol use interventions, ages 17-70 years | 370 | 50.9 | 38.2 | NR | NR | AUDIT
Adults | Foxcroft, 2015^110^ | Good | GBR | Primary care | Adults, ages 18-35 years | 420 | NR | 67.1 | White: 86.0 Black: NR Hispanic: NR | IMD Quintile I (lowest deprivation): 53.0% | AUDIT, AUDIT-C
Adults | Gache, 2005^111^ | Good | FRA, CHE | Primary care | Adults, age ≥18 years, nonabstainers | 1207 | 43.3 | 51.6 | NR | NR | AUDIT
Adults | Gomez, 2005^112^ | Fair | ESP | Primary care | Adults, age ≥15 years | 500 | 44 | 56.2 | NR | NR | AUDIT, AUDIT-C, 6+ drinks
Adults | Gomez, 2006^113^ | Fair | ESP | Primary care | Adults receiving primary care services, age ≥15 years | 602 | 48.7 | 55.0 | NR | NR | AUDIT, AUDIT-C
Adults | Gual, 2002^115^ | Fair | ESP | Primary care | Adults attending primary health care appointment, age ≥17 years | 255 | 44.0 | 50.2 | NR | Employed: 73% HS grad or higher: 39% | AUDIT, AUDIT-C
Adults | Isaacson, 1994^117^ | Fair | US | Primary care | Adults, new patients at an inner-city primary care clinic | 124 | 45 | 52 | NR | Clinic serves a population that is predominantly of lower SES | AUDIT
Adults | Kumar, 2016^121^ | Good | US | Primary care | Adults, age ≥18 years | 399 | 46.8 | 48.4 | White: 19.8 Black: 47.9 Hispanic: NR | HS degree or higher: 82.5% Income <$50,000: 79.4% Employed, full-time: 20.0% Employed, part-time: 9.3% | ASSIST
Adults | Levola, 2015^122^ | Fair | FIN | Other medical | FINRISK adults, ages 25-60 years, reporting at least mild (BDI-SF score ≥4) or moderate (≥8) symptoms of depression | 556 | 44.7 | 57.4 | NR | NR | AUDIT, AUDIT-C, 6+ drinks
Adults | McCann, 2000^124^ | Fair | US | Other medical | Adults seeking evaluation for ADHD | 139 | 36.4 | 30.9 | White: 95.7 Black: NR Hispanic: NR | NR | AUDIT
Adults | McGinnis, 2013^125^ | Fair | US | Primary care | Male VA patients, HIV-infected patients and matched controls, at least 1 alcoholic beverage in past year | 837 | 52 | 0 | White: 33 Black: 53 Hispanic: 8 | NR | AUDIT, AUDIT-C, 6+ drinks
Adults | McNeely, 2015^126^ | Good | US | Primary care | Adults, ages 21-65 years | 586 | 46 | 49.8 | White: 18.7 Black: 50.2 Hispanic: 21.7 | HS degree or higher: 84.1% Income <$50,000: 79.5% | 4+ drinks, 5/4+ drinks
Adults | McNeely, 2016^136,^ ^147^ | Fair | US | Primary care | Adults, age ≥18 years | 2000 | 46 | 56.2 | White: 33.4 Black: 55.6 | HS degree or higher: 79.8% Unemployed: 21.0% | 5/4+ drinks
Adults | Piccinelli, 1997^128^ | Fair | ITA | Primary care | Adults, ages 18-65 years | 482 | 42.2 | 63.5 | NR | HS degree or higher: 33.6% Employed: 56.8% | AUDIT
Adults | Rumpf, 2002^129^ | Fair | DEU | Community-based | Adults, ages 18-64 years, consuming alcohol in the past 12 months | 3551 | 41.2 | 49.2 | NR | HS degree or higher: 22.1% | AUDIT, AUDIT-C
Adults | Seale, 2006^132^ | Fair | US | Primary care | Adult drinkers attending primary care practices, 6+ drinks in the previous year | 625 | 40.9 | 54.4 | White: 60.8 Black: 38.1 Hispanic: 1.1 | NR | AUDIT, AUDIT-C, 5/4+ drinks
Adults | Smith, 2009^133^ | Good | US | Primary care | Adults attending a primary care clinic, age ≥18 years | 286 | 49 | 54.2 | White: 17.1 Black: 62.6 Hispanic: 16.1 | HS degree or higher: 71.7% | AUDIT-C, 5/4+ drinks
Adults | Volk, 1997^134^ | Fair | US | Primary care | Adults attending primary care visits, age ≥18 years, self-identified as white, black, or Hispanic | 1333 | 43.2 | 70.7 | White: 38.4 Black: 35.3 Hispanic: 26.3 | No more than high school degree: White: 31.1% Black: 45.2% Hispanic: 26.3% Annual income <$20,000 White: 36.6% Black: 68.5% Hispanic: 59.3% | AUDIT, AUDIT-C
Older adults | Aalto, 2011^94^ | Good | FIN | Community-based | Older adults, ages 65-74 years | 517 | 69.0 | 49.7 | NR | NR | AUDIT, AUDIT-C, Quantity x Frequency, 6+ drinks, 4+ drinks
Older adults | Dawson, 2005^106,^ ^139^ | Good | US | Community-based | Adult participants in the 2001-2002 NESARC, age ≥65 years (for this subgroup only) | 8666 | NR | NR | NR | NR | AUDIT-C, 5/4+ drinks Maximum drinks
Pregnant women | Bull, 1999^100^ | Fair | US | Primary care | Pregnant women attending prenatal appointments (mean, 15.2 weeks’ gestation), American Indian or carrying an American Indian baby, ages 15-44 years | 208 | 24.4 | 100.0 | NR | NR | Quantity x Frequency
Pregnant women | Dawson, 2005^106,^ ^139^ | Good | US | Community-based | Adult participants in the 2001-2002 NESARC, age ≥18 years, pregnant past-year drinkers (this subgroup only) | 256 | NR | 100.0 | NR | NR | AUDIT-C
Pregnant women | Lopez, 2017^135^ | Fair | ARG | Hospital | Postpartum women, ages 13-44 years | 641 | 25.6 | 100.0 | NR | ≥12 years of formal education: 38% | AUDIT, AUDIT-C, T-ACE, TWEAK

* Race/ethnicity for the full sample (n=1193).

Abbreviations: ARG = Argentina; ASSIST = Alcohol, Smoking and Substance; AUDIT = Alcohol Use Disorders Identification Test; AUDIT-C = Alcohol Use Disorders Identification Test-Consumption; ESP = Spain; FRA = France; HS = high school; KQ = key question; NESARC = National Epidemiologic Survey on Alcohol and Related Conditions; NR = not reported; SES = socioeconomic status; US = United States; VA = U.S. Department of Veterans Affairs.

Table 5 Summary Population Characteristics for Key Question 2

Population | No. studies | No. participants | No. (%) good quality | No. (%) conducted in U.S. | Other countries represented | No. (%) in primary care | Other settings | Average age^†^ | % Female^†^ | No. (%) studies majority nonwhite
All populations | 45 * | 277,938 | 17 (38) | 28 (62) | | 23 (51) | | 35.3 | 49.6 | 13 (29)
Adolescents | 10 | 171,363 | 5 (50) | 8 (80) | CHL, DEU | 7 (70%) | High school (2), Community (1) | 15.5 | 48.8 | 5 (50)
Adults (nonpregnant/postpartum) | 35 | 114,182 | 14 (40) | 21 (60) | | 16 (46) | | 38.1 | 53.1 | 7 (20)
Young adults | 6 | 6,376 | 4 (67) | 5 (83) | BEL | 1 (17) | University (4), Other medical (1) | 18.5 | 57.5 | 1 (17)
Adults | 27 | 99,084 | 8 (30) | 15 (56) | AUS, DEU, ESP, FIN, FRA, CHE, UK, ITA, NLD | 15 (56) | Other medical (5), Community (6), University (1) | 43.3 | 51.8 | 6 (22)
Older adults | 2 | 8,722 | 2 (100) | 1 (50) | FIN | 0 (0) | Community (2) | 69.0 | 49.7 | 0 (0)
Pregnant women | 3 | 1,105 | 1 (33) | 2 (67) | ARG | 1 (33) | Community (1), Hospital (1) | 25.3 | 100 | 2 (67)

* Three studies included subgroup analyses in young adults, older adults, and pregnant women, which are shown in the rows for these populations; therefore, the sum of the rows do not add up to the “All populations” totals.

† Weighted by n randomized.

Abbreviations: AUS = Australia; ARG = Argentina; BEL = Belgium; CHE = Czech Republic; CHL = Chile; DEU = Germany; ESP = Spain; FIN = Finland; FRA = France; ITA = Italy; NLD = Netherlands; No. = number; UK = United Kingdom; US = United States.

Reference standards used in the included studies were most commonly structured diagnostic interviews (e.g., Composite International Diagnostic Interview, Alcohol Use Disorder and Associated Disabilities Interview Schedule, Mini International Neuropsychiatric Interview Plus), and sometimes the interview was used in combination with other instruments (e.g., with the ASSIST to identify the full spectrum of unhealthy use) or with the Timeline Followback (TLFB). Definitions of unhealthy use and exceeding limits were variable, as recommendations differ across countries. The majority of the studies were fair quality (28/45 [62%]). Among the studies that were rated as fair quality, the most common reasons for increased risk of bias included: not reporting enough information regarding the order and timing of the reference standard and screening test; not clearly reporting on whether the researchers had knowledge of the index test results during the administration and interpretation of the reference standard; not presenting a range of cutoff values or an a priori threshold; and/or not reporting whether participant recruitment was random or consecutive.

### Summary of Results

Table 6 summarizes the test accuracy of the most commonly used screening instruments (one- or two-item questions, AUDIT-C, and AUDIT) for detecting full spectrum of unhealthy alcohol use (including exceeding daily or weekly limits, exceeding heavy use episode limits, and meeting criteria for AUD) and AUD (any level of severity, including both abuse and dependence). Forest plots show study-level results for detecting unhealthy use (Figures 1-7) and AUD (Figures 8-13). In addition, detailed information on the use of these instruments to detect alcohol dependence or severe AUD is available in Appendix G.

Table 6 Sensitivity and Specificity Range for One- or Two-Item Screeners, AUDIT-C, and AUDIT

Population (No. studies) | Condition | One- or two-item, optimal cutoff | NIAAA-recommended^*^ | AUDIT-C, ≥3 cutoff (female) | AUDIT-C, ≥4 cutoff (male) | AUDIT-C, optimal cutoff | AUDIT, ≥8 cutoff | AUDIT, optimal cutoff | AUDIT, ≥3/4/5 cutoff, US primary care
Adolescents (10) | Unhealthy Alcohol Use | None | None | None | None | Se: 0.73 Sp: 0.81 k=1, n=225 | Se: 0.66 Sp: 0.86 k=1, n=225 | Se: 0.79 Sp: 0.79 k=1, n=225 | None
Adolescents (10) | AUD | Se: 0.87-1.0 Sp: 0.84-0.95 k=5, n=3564 | Se: 0.87-1.0 Sp: 0.84-0.94 k=3, n=2486 | None | None | Se: 0.76 Sp: 0.78 k=1, n=225 | Se: 0.54-0.71 Sp: 0.84-0.97 k=3, n=2332 | Se: 0.84-0.88 Sp: 0.77 k=2, n=763 | Se: 0.88 Sp: 0.77 k=1, n=538
Young Adults (6) | Unhealthy Alcohol Use | None | None | Se: 0.98 Sp: 0.47 k=1, n=217 | Se: 0.97 Sp: 0.40 k=1, n=184 | Se: 0.80-0.82^†^ Sp: 0.82-0.88^†^ k=1, n=401 | Se: 0.82 Sp: 0.78-0.79 k=2, n=703 | Se: 0.82-0.88 Sp: 0.70-0.79 k=2, n=703 | None
Young Adults (6) | AUD | Se: 0.81-0.92 Sp: 0.75-0.80 k=1, n=251 | None | None | None | None | Se: 0.68-0.82 Sp: 0.72-0.75 k=2, n=660 | Se: 0.73-0.82 Sp: 0.67-0.78 k=3, n=4224 | None
Adults (27) | Unhealthy Alcohol Use | Se: 0.65-0.90 Sp: 0.68-1.0 k=8, n=48,211 | Se: 0.73-0.88 Sp: 0.74-1.0 k=4, n=44,461 | Se: 0.73-0.97 Sp: 0.28-0.91 k=5, n=2714 | Se: 0.82-1.0^‡^ Sp: 0.34-0.89^‡^ k=4, n=1038 | Se: 0.74-0.92^‡^ Sp: 0.66-0.89^‡^ k=8, n=9447 | Se: 0.38-0.73 Sp: 0.89-0.97 k=7, n=8852 | Se: 0.68-0.91 Sp: 0.75-0.96 k=9 n=9832 | Se: 0.64-0.86 Sp: 0.74-0.94 k=3, n=2782
Adults (27) | AUD | Se: 0.71-0.94 Sp: 0.60-0.91 k=7, n=46,985 | Se: 0.71-0.92 Sp: 0.60-0.91 k=6, n=46,244 | Se: 0.78-0.87 Sp: 0.69-0.85 k=3, n=15,167 | Se: 0.87-0.88 Sp: 0.63-0.75 k=3, n=14,873 | Se: 0.70-0.88 Sp: 0.70-0.85 k=6, n=82,444 | Se: 0.43-0.96 Sp: 0.82-0.96 k=6, n=4908 | Se: 0.48-0.96 Sp: 0.34-0.96 k=8, n=5746 | Se: 0.72-0.83 Sp: 0.67-0.88 k=2, n=1958
Older Adults (2) | Unhealthy Alcohol Use | Se: 0.64-0.97 Sp: 0.70-1.0 k=2, n=9183 | Se: 0.64 Sp: 1.0 k=1, n=8666 | None | None | Se: 0.94 Sp: 0.80 k=1, n=517 | Se: 0.48 Sp: 0.97 k=1, n=517 | Se: 0.86 Sp: 0.87 k=1, n=517 | None
Older Adults (2) | AUD | None | None | None | None | Se: 0.76 Sp: 0.74 k=1, n=8205 | None | None | None
Pregnant Women (3) | Use | Se: 0.77 Sp: 0.93 k=1, n=208 | None | None | None | None | None | None | None
Pregnant Women (3) | Unhealthy Alcohol Use | None | None | None | None | None | None | None | None
Pregnant Women (3) | AUD | None | None | Se: 0.90-0.96 Sp: 0.71-0.79 k=2, n=897 | NA | Se: 0.90-0.96 Sp: 0.71-0.79 k=2, n=897 | None | Se: 0.87 Sp: 0.86 k=1, n=641 | None

* NIAAA-recommended screening instrument for adults: “How many times in the past year have you had 5/4 (M/F) or more drinks in a day?” preceded by a prescreening question that assessed alcohol use (“Do you sometimes drink beer, wine, or other alcoholic beverages?”). NIAAA-recommended screening instrument for adolescents: “Do you have any friends who drank beer, wine, or any drink containing alcohol in the past year?” and “In the past year, on how many days have you had more than a few sips of beer, wine, or any drink containing alcohol?” (For ages 9-14 years, the first question asks about friends’ use; for ages 14-18 years, the first question asks about personal use).^98^

† More than one value reported because data was presented by subgroups (e.g., sex, race).

‡ McGinnis et al^125^ was an outlier and was not included in the ranges presented. It reported the following: for AUDIT-C, ≥4 cutoff (male), sensitivity of 0.63 and specificity of 0.90 for unhealthy alcohol use.

Abbreviations: AUD = alcohol use disorder; AUDIT = Alcohol Use Disorders Index Test; AUDIT-C = Alcohol Use Disorders Index Test, Consumption; NA = not applicable; NIAAA = National Institute on Alcohol Abuse and Alcoholism; Se = sensitivity; Sp = specificity; US = United States.

Figure 1 Test Accuracy of One- or Two-Item Screening Tests at the Optimal* Cutoff to Detect Unhealthy Alcohol Use (KQ2)

* Optimal cutoffs could vary by study and were selected as either the optimal cutoff determined by the authors or the reviewers.

Abbreviations: CI = confidence interval; freq = frequency; KQ = key question; n = number of participants; quant = quantity.

Note: McGinnis is an all male study. 4+ drinks includes modified AUDIT-3 (lower threshold for females and older adults) and SUBS. 6+ drinks includes AUDIT-3. Quant x Freq includes the first two items from the AUDIT; the score can range from 0 to 8.

This figure shows the test accuracy of one- or two-item screening tests at the optimal cutoff to detect unhealthy alcohol use.

Figure 2 Test Accuracy of the AUDIT-C at Cutoff of ≥3 to Detect Unhealthy Alcohol Use Among Females (KQ2)

Abbreviations: AUDIT-C = Alcohol Use Disorders Identification Test, Consumption; CI = confidence interval; KQ = key question; n = number of participants analyzed.

This figure shows the test accuracy of the AUDIT-C at a cutoff of ≥3 to detect unhealthy alcohol use among females.

Figure 3 Test Accuracy of the AUDIT-C at Cutoff of ≥4 to Detect Unhealthy Alcohol Use Among Males (KQ2)

Abbreviations: AUDIT-C = Alcohol Use Disorders Identification Test, Consumption; CI = confidence interval; KQ = key question; n = number of participants analyzed.

This figure shows the test accuracy of the AUDIT-C at a cutoff of ≥4 to detect unhealthy alcohol use among males.

Figure 4 Test Accuracy of the AUDIT-C at the Optimal* Cutoff to Detect Unhealthy Alcohol Use (KQ2)

* Optimal cutoffs could vary by study and were selected as either the optimal cutoff determined by the authors or the reviewers.

Abbreviations: AUDIT-C = Alcohol Use Disorders Identification Test, Consumption; CI = confidence interval; KQ = key question; n = number of participants analyzed.

This figure shows the test accuracy of the AUDIT-C at the optimal cutoff to detect unhealthy alcohol use.

Figure 5 Test Accuracy of the AUDIT at Cutoff of ≥8 to Detect Unhealthy Alcohol Use Among Adolescents, Young Adults, Adults, and Older Adults (KQ2)

Abbreviations: AUDIT = Alcohol Use Disorders Identification Test; CI = confidence interval; KQ = key question; n = number of participants analyzed.

This figure shows the test accuracy of the AUDIT at a cutoff of ≥8 to detect unhealthy alcohol use among adolescents, young adults, adults, and older adults.

Figure 6 Test Accuracy of the AUDIT at the Optimal* Cutoff to Detect Unhealthy Alcohol Use (KQ2)

* Optimal cutoffs could vary by study and were selected as either the optimal cutoff determined by the authors or the reviewers.

Abbreviations: AUDIT = Alcohol Use Disorders Identification Test; CI = confidence interval; KQ = key question; n = number of participants analyzed.

Note: Degernhardt et al^108^ did not provide confidence intervals and is not in the figure (adult males, cutoff ≥11: sensitivity, 0.784; specificity, 0.755; adult females, cutoff ≥9: sensitivity, 0.681; specificity, 0.864).

This figure shows test accuracy of the AUDIT at the optimal cutoff to detect unhealthy alcohol use.

Figure 7 Test Accuracy of the AUDIT to Detect the Full Spectrum of Unhealthy Alcohol Use or Alcohol Use Disorder, at Cutoffs of ≥3, 4, or 5, in U.S.-Based Primary Care (KQ2)

Abbreviations: AUDIT= Alcohol Use Disorders Identification Test; CI = confidence interval; KQ = key question; n = number of participants analyzed.

This figure shows the test accuracy of the AUDIT to detect the full spectrum of unhealthy alcohol use or alcohol use disorder, at cutoffs of ≥3, 4, or 5, in U.S.-based primary care.

Figure 8 Test Accuracy of One- or Two-Item Screening Tests* at the Optimal Cutoff to Detect Alcohol Use Disorder (KQ2)

* 4+ drinks includes SUBS. 5/4+ drinks includes TAPS-1.

Abbreviations: CI = confidence interval; KQ = key question; mod = moderate; n = number of participants analyzed; NIAAA = National Institute on Alcohol Abuse and Alcoholism; wk = week.

This figure shows the test accuracy of one- or two-item screening tests at the optimal cutoff to detect alcohol use disorder.

Figure 9 Test Accuracy of the AUDIT-C at Cutoff of ≥3 to Detect Alcohol Use Disorder Among Females (KQ2)

Abbreviations: AUDIT-C = Alcohol Use Disorders Identification Test, Consumption; CI = confidence interval; KQ = key question; n = number of participants analyzed.

This figure shows the test accuracy of the AUDIT-C at cutoff of ≥3 to detect alcohol use disorder among females.

Figure 10 Test Accuracy of the AUDIT-C at Cutoff of ≥4 to Detect Alcohol Use Disorder Among Males (KQ2)

Abbreviations: AUDIT-C = Alcohol Use Disorders Identification Test, Consumption; CI = confidence interval; KQ = key question; n = number of participants analyzed.

This figure shows the test accuracy of the AUDIT-C at a cutoff of ≥4 to detect alcohol use disorder among males.

Figure 11 Test Accuracy of the AUDIT-C at the Optimal Cutoff to Detect Alcohol Use Disorder (KQ2)

Abbreviations: AUDIT-C = Alcohol Use Disorders Identification Test, Consumption; CI = confidence interval; KQ = key question; n = number of participants analyzed.

This figure shows the test accuracy of the AUDIT-C at the optimal cutoff to detect alcohol use disorder.

Figure 12 Test Accuracy of the AUDIT at Cutoff of ≥8 to Detect Alcohol Use Disorder (KQ2)

Abbreviations: AUDIT-C = Alcohol Use Disorders Identification Test, Consumption; CI = confidence interval; KQ = key question; n = number of participants analyzed.

This figure shows the test accuracy of the AUDIT at a cutoff of ≥8 to detect alcohol use disorder.

Figure 13 Test Accuracy of the AUDIT at the Optimal Cutoff to Detect Alcohol Use Disorder (KQ2)

Abbreviations: AUDIT = Alcohol Use Disorders Identification Test; CI = confidence interval; KQ = key question; n = number of participants analyzed.

This figure shows the test accuracy of the AUDIT at the optimal cutoff to detect alcohol use disorder.

For adolescents, just one study (n=225) in a German high school reported on the test accuracy for detecting the full spectrum of unhealthy alcohol use (Figure 4), finding a sensitivity of 0.73 (95% CI, 0.60 to 0.83) and specificity of 0.81 (95% CI, 0.74 to 0.86) for the optimal cutoff of 5 or higher on the AUDIT-C (males and females combined). Multiple studies demonstrated good test accuracy of one- or two-item screeners and the AUDIT for detecting AUD. For example, the NIAAA-recommended single question (“In the past year, on how many days have you had more than a few sips of beer, wine, or any drink containing alcohol?”) had sensitivity ranging from 0.87 to 1.00 (95% CI range, 0.76 to 1.0) and specificity ranging from 0.84 to 0.94 (95% CI range, 0.82 to 0.97; k=3; n=2,486) (Figure 8), and other one- or two-item screeners showed similar results. All five studies addressing one- or two-item screeners were conducted in primary care settings in the United States, and in several studies the samples were comprised primarily of black and Hispanic youth.

For adults, studies of the NIAAA-recommended single-item question (“How many times in the past year have you had 5/4 [males/females] or more drinks in a day?”) reported sensitivity ranging from 0.73 to 0.88 (95% CI range, 0.65 to 0.89) and specificity ranging from 0.74 to 1.0 (95% CI range, 0.69 to 1.0) for detecting unhealthy alcohol use (k=4; n=44,461) (Figure 1). All of these studies were conducted in the United States, primarily in primary care settings. Other one- or two-item screeners generally showed sensitivities of 0.70 or greater, although the standard of six or more drinks per occasion tended to have lower sensitivity than the five/four or more drinks standard, often with nonoverlapping CIs. Other adult populations (young adults, older adults, pregnant women) had results in similar ranges. When used for detecting AUD instead of the full spectrum of unhealthy use, the ranges were largely overlapping but shifted slightly higher for sensitivity and lower for specificity.

For the AUDIT-C, sensitivity for detecting unhealthy alcohol use in adults was similar to the one- or two-item screeners, excluding one VA-based study in HIV-positive patients and matched controls^125^ that had substantially lower sensitivity. In most studies, the range of sensitivity was 0.73 to 0.97 for females (95% CI range, 0.62 to 0.99; k=5; n=2,714) (Figure 2) and 0.82 to 1.0 for males (95% CI range, 0.75 to 1.0; k=4; n=1,038) (Figure 3) at the standard cutoffs of 3 or higher for females and 4 or higher for males, but the range of reported specificity was much wider (0.28 to 0.91 [95% CI range, 0.21 to 0.93] and 0.34 to 0.89 [95% CI range, 0.25 to 0.92], for females and males, respectively). A number of studies reported sensitivity of 0.80 or greater at optimal cutoffs on the AUDIT-C, with associated specificity generally in range of mid-0.70s to mid-0.80s (Figure 4). Results generally showed similar ranges when detecting AUD rather than the full spectrum of unhealthy alcohol use, except with some higher specificity values at the standard cutoffs. Evidence on the use of the AUDIT-C was very sparse in the adult subpopulations of younger adults, older adults, and pregnant women.

For the AUDIT, when using the recommended cutoff of 8 or higher, studies reported a wide range of sensitivity for detecting unhealthy alcohol use in general adult populations (0.38 to 0.73 [95% CI range, 0.33 to 0.84]) but high specificity (0.89 to 0.97 [95% CI range, 0.84 to 0.98]; k=7; n=8,852) (Figure 5). Sensitivity was relatively high (0.82) in young adults at the standard cutoff of 8 or higher, but data were sparse in this population (k=2; n=660). In many studies, sensitivity improved at lower cutoffs. Studies conducted in U.S.-based primary care settings showed a more optimal balance of sensitivity and specificity at cutoffs of 3, 4, or 5 (sensitivity range, 0.64 to 0.86 [95% CI range, 0.57 to 0.91]; specificity range, 0.74 to 0.94 [95% CI range, 0.68 to 0.95]; k=3; n=2,782) (Figure 7). Both sensitivity and specificity values tended to be wider ranging across studies for detecting AUD than for detecting unhealthy use when using the AUDIT.

For all studies, subgroup analyses commonly identified different optimal cutoffs for different subgroups. In several instances, optimal cut-points were lower for females than for males, for blacks than for whites, and for the very young and older ages than for general adults. However, with little replication and sometimes conflicting results, evidence does not clearly support any specific alternate cut-points for the subgroups and instruments explored. One study^109^ among young adults reported test accuracy for male and female subgroups to detect unhealthy alcohol use employing the AUDIT and AUDIT-C. The optimal cutoff for the AUDIT was 8 or higher for both sexes; for the AUDIT-C, females had a lower cutoff than males (≥5 vs. ≥7). Another study among young adults found lower optimal cutoffs for the AUDIT and AUDIT-C for females versus males.^127^ For adults, four studies found lower optimal cut-points for females than males on both the AUDIT and the AUDIT-C;^93,^ ^115,^ ^122,^ ^134^ however, one of these^134,^ ^140^ reported no difference in performance characteristics by sex at the standard cutoffs for the AUDIT. Three studies examining single-item screeners found no difference in test accuracy between males and females^106,^ ^126,^ ^133^ but one study found lower optimal cutoffs for females.^106,^ ^139^

Race/ethnicity differences were suggested in some, but not all, studies. One study among young adults reported the same cutoffs for the AUDIT for white and black males, but lower for black females versus white females.^127^ The same study^127^ reported lower cutoffs for the AUDIT-C for black versus white participants. For general adults, race/ethnicity differences in the optimal cutoffs were reported for single-item screeners in one study, with higher optimal cutoffs for American Indian, white, and Hispanic participants versus Asian and black participants,^106,^ ^139^ but no statistically significant difference was found for race/ethnicity in two other studies.^126,^ ^133,^ ^144^ Volk and colleagues^134,^ ^140^ reported no difference by race/ethnicity for the AUDIT, and while the test accuracy in the same group of participants varied by race/ethnicity for the AUDIT-C, the authors did not recommend using different cutoffs for race/ethnicity in practice.

Socioeconomic status was examined in two studies of single-item screening tests, with no difference reported.^126,^ ^133^

In general, older adults^94,^ ^106^ tended to have lower optimal cutoffs than the general adult population. Among adolescents, one study suggested lower cutoffs to detect alcohol dependence for single-item screeners,^101^ but in another study, the optimal cutoffs remained the same for younger (ages 12 to 14 years) and older (ages 15 to 17 years) adolescents to detect AUD.^102^ When comparing adolescents (ages 12 to 17 years) to young adults (ages 18 to 20 years) within the same study, the optimal cutoffs to detect AUD were higher for young adults.^102^

### Detailed Results

#### Adolescents

##### Study and Population Characteristics

Five good-quality^101,^ ^102,^ ^105,^ ^116,^ ^119^ and five fair-quality^114,^ ^118,^ ^123,^ ^130,^ ^131^ studies recruited adolescent participants, usually ages 12 to 17 years. Seven studies were conducted in U.S. primary care patients,^102,^ ^105,^ ^114,^ ^116,^ ^118,^ ^119,^ ^123^ one recruited a community-based sample in the United States,^101^ and the two studies conducted outside the United States (Germany, Chile) recruited participants from schools.^130,^ ^131^ Studies ranged in size from 95^131^ to 166, 165^101^ participants; all but one of the studies had fewer than 1,600 participants. The mean age was 15 or 16 years in six studies; four studies did not report mean age.^101,^ ^114,^ ^118,^ ^123^ The number of females ranged from 44^131^ to 68^119^ percent. Race/ethnicity was reported in the eight U.S.-based studies. Three studies had a majority of white participants (62% to 93%),^101,^ ^102,^ ^123^ three studies had a majority of black participants (51% to 93%),^114,^ ^118,^ ^119^ and two others had a majority of nonwhite participants (82% to 85%).^105,^ ^116^ One study^123^ restricted eligibility to adolescents who had been diagnosed for a year or longer with type 1 diabetes, asthma, cystic fibrosis, inflammatory bowel disease, or juvenile idiopathic arthritis.

Only one study reported the prevalence of unhealthy alcohol use (24.9%).^130^ In seven studies,^102,^ ^105,^ ^114,^ ^116,^ ^118,^ ^119,^ ^123^ the prevalence of AUD ranged from 2.9 to 7.6 percent (dependence ranged from 2.2%^119^ to 2.5%^101^ in two studies). One study,^130^ recruiting students from a comprehensive school in Germany, had a much higher prevalence of AUD at 20.0 percent (dependence, 3.1%).

One study evaluated the test accuracy for identifying unhealthy use,^130^ eight studies for identifying AUD,^102,^ ^105,^ ^114,^ ^116,^ ^118,^ ^119,^ ^123,^ ^130^ and four studies for identifying dependence.^101,^ ^102,^ ^119,^ ^131^ Four studies assessed the test accuracy of the AUDIT, one studied the AUDIT-C, one studied the ASSIST, and six studies examined various one- or two-item screeners. For all conditions, all studies used a structured clinical interview (e.g., Composite International Diagnostic Interview, Adolescent Drinking Index, Diagnostic Interview Schedule for Children, Version Four) as the reference standard.

##### Full Spectrum of Unhealthy Alcohol Use

###### One- or Two-Item

No studies among adolescents reported on test accuracy for using a one- or two-item test to screen for the full spectrum of unhealthy alcohol use. One study,^105^ using a one- or two-item test to screen for persons exceeding recommended limits, reported a sensitivity of 0.56 (95% CI, 0.51 to 0.61) and specificity of 0.92 (95% CI, 0.90 to 0.93) (Appendix H Figure 5, Appendix I Table 4).

###### AUDIT-C

One study^130^ (n=225) reported a sensitivity of 0.73 (95% CI, 0.60 to 0.83) and specificity of 0.81 (95% CI, 0.74 to 0.86) for the optimal cutoff of 5 or higher for males and females combined (Figure 4, Appendix I Table 1) in a sample with high levels of AUD. One study reported sensitivity of 0.85 (95% CI, 0.69 to 0.93) and specificity of 0.77 (95% CI, 0.71, 0.82) at the optimal cutoff of 5 or higher to detect persons exceeding recommended limits^130^ (Appendix H Figure 6, Appendix I Table 4).

###### AUDIT

The same study^130^ (n=225) reported a sensitivity of 0.66 (95% CI, 0.53 to 0.77) and specificity of 0.86 (95% CI, 0.80 to 0.90) when using the standard cutoff of 8 or higher (Figure 5, Appendix I Table 1). The optimal cutoff reported in this study was 6 or higher, with a sensitivity of 0.79 (95% CI, 0.66 to 0.87) and specificity of 0.79 (95% CI, 0.73 to 0.85) (Figure 6, Appendix I Table 1). Two studies^130,^ ^131^ reported sensitivity ranging from 0.85 to 0.96 (95% CI range, 0.69 to 1.0) and specificity ranging from 0.63 to 0.73 (95% CI range, 0.48 to 0.79) to detect persons exceeding recommended limits using the AUDIT at the optimal cutoffs of 3 and 6 (Appendix H Figure 7, Appendix I Table 4).

###### ASSIST

No studies in adolescents reported on test accuracy for using the ASSIST to screen for the full spectrum of unhealthy alcohol use.

##### AUD

###### One- or Two-Item

Five studies^102,^ ^105,^ ^116,^ ^118,^ ^123^ (n=3,564) reported test accuracy for four variations of a one- or two-item screening test^102,^ ^105,^ ^116,^ ^118,^ ^123^ (Figure 8, Appendix I Table 2), with sensitivity ranging from 0.87 to 1.0 (95% CI range, 0.68 to 1.00) and specificity ranging from 0.84 to 0.95 (95% CI range, 0.82 to 0.97). Three studies^105,^ ^118,^ ^123^ (n=2,486) followed a screening approach recommended by the NIAAA that asks about friends’ and personal use of alcohol; sensitivity ranged from 0.87 to 1.00 (95% CI range, 0.76 to 1.0) and specificity ranged from 0.84 to 0.94 (95% CI range, 0.82 to 0.97).

###### AUDIT-C

One study^130^ (n=225) reported a sensitivity of 0.76 (95% CI, 0.61 to 0.86) with a corresponding specificity of 0.78 (95% CI, 0.71 to 0.83) at the optimal cutoff of 5 or higher for males and females combined (Figure 11, Appendix I Table 2).

###### AUDIT

Three studies examined the test accuracy of the AUDIT at a cutoff of 8 or higher (Figure 12, Appendix I Table 2).^105,^ ^119,^ ^130^ Sensitivity was similar among two studies at 0.70 (95% CI, 0.57 to 0.81)^105^ and 0.71 (95% CI, 0.57 to 0.82),^130^ with a widely ranging proportion with AUD (3.9% and 20%); the third study reported a sensitivity of 0.54 (95% CI, 0.38 to 0.69).^119^ Specificity ranged from 0.84 to 0.97 (95% CI range, 0.78 to 0.98). A lower optimal cutoff was reported for two studies, at 3 or higher^119^ and 6 or higher.^130^ Sensitivity increased (0.84 and 0.88 [95% CI range, 0.71 to 0.97]), but specificity decreased (0.77 [95% CI range, 0.71 to 0.83]) for these lower cutoffs (Figure 13). One study^119^ conducted in a U.S. primary care sample also reported the test accuracy of the AUDIT at a cutoff of 5 or higher, with sensitivity of 0.73 (95% CI, 0.58 to 0.87) and specificity of 0.88 (95% CI, 0.85 to 0.91) (Figure 7, Appendix I Table 2).

###### ASSIST

One study^114^ used the ASSIST with a cutoff of 2 or higher to screen for DSM-5-defined AUD; sensitivity was 1.00 (95% CI, 0.86 to 1.00) and specificity was 0.79 (95% CI, 0.75 to 0.82) (Appendix I Table 2).

#### Young Adults

##### Study and Population Characteristics

Four good-quality studies^84,^ ^102,^ ^109,^ ^120^ and two fair-quality studies^95,^ ^127^ recruited young adults. One of the good-quality studies included adolescents ages 12 to 20 years and reported results for a young adult subgroup (ages 18 to 20 years).^102^ Five studies were conducted in the United States, three from college/university settings,^109,^ ^120,^ ^127^ one from primary care,^102^ and one from a sexually transmitted infection clinic.^84^ The sixth study was conducted at a university in Belgium.^95^ Mean age ranged from 18 to 21 years, and the proportion of female participants ranged from 45 to 68 percent. Three studies^109,^ ^120,^ ^127^ had a majority of white participants (64% to 90%) and one study^84^ had 46 percent white and 49 percent black participants. Race/ethnicity was not reported in the Belgian study or for the subgroup of young adults. Sample size ranged from 251 to 3,564 participants. Socioeconomic status was not reported in any of the six included studies.

Two studies evaluated the test accuracy for identifying unhealthy use (prevalence ranged from 28.1% to 52%),^109,^ ^120^ four studies for identifying AUD (prevalence ranged from 10.0% to 43.4%),^84,^ ^95,^ ^102,^ ^120^ and two for identifying dependence (Appendix G).^95,^ ^127^ Five studies assessed test accuracy of the AUDIT, two evaluated the AUDIT-C,^109,^ ^127^ and one examined a variety of one- or two-item screening questions.^102^ For unhealthy use, one study used a structured clinical interview and one used the TLFB as reference standards. For use disorder and dependence, all studies used a structured clinical interview for the reference standard.

##### Full Spectrum of Unhealthy Alcohol Use

###### One- or Two-Item

No included studies that focused on young adults reported on test accuracy for using one- or two-item tests to screen for the full spectrum of unhealthy alcohol use.

###### AUDIT-C

One study^109^ reported sensitivity of 0.98 (95% CI, 0.93 to 0.99) and specificity of 0.47 (95% CI, 0.38 to 0.56) for females at a cutoff of 3 or higher (Figure 2, Appendix I Table 6). The optimal cutoff in this study was 5 or higher for females (sensitivity, 0.82 [95% CI, 0.73 to 0.88]; specificity, 0.82 [95% CI, 0.74 to 0.88]) (Figure 4). For males at a cutoff of 4 or higher, sensitivity was 0.97 (95% CI, 0.92 to 0.99) and specificity was 0.40 (95% CI, 0.30 to 0.50) (Figure 3). The optimal cutoff was 7 or higher for males (sensitivity, 0.80 [95% CI, 0.71 to 0.86]; specificity, 0.88 [95% CI, 0.79 to 0.93]) (Figure 4).

###### AUDIT

Two studies^109,^ ^120^ assessed the test accuracy of the AUDIT to screen for unhealthy alcohol use (Appendix I Table 6). At a cutoff of 8 or higher, also the optimal cutoff for one study,^109^ sensitivity was 0.82 in both studies (95% CI range, 0.72 to 0.88) and specificity was 0.79 and 0.78 (95% CI range, 0.72 to 0.84) (Figure 5). The optimal cutoff was 7 or higher for one study (sensitivity, 0.88 [95% CI, 0.79 to 0.93]; specificity, 0.70 [95% CI, 0.64 to 0.76]) (Figure 6).^120^

###### ASSIST

No studies in young adults reported on test accuracy for using the ASSIST to screen for the full spectrum of unhealthy alcohol use.

##### AUD

###### One- or Two-Item

One study^102^ (n=251) assessed the test accuracy of three variations of a one- or two-item screening question to screen for AUD, assessing frequency (drinking days in the previous year), quantity (drinks per drinking day), and the combination (total drinks consumed in the previous year) (Figure 8, Appendix I Table 7). Sensitivity ranged from 0.81 to 0.92 (95% CI range, 0.61 to 0.98) and specificity ranged from 0.75 to 0.80 (95% CI range, 0.69 to 0.85). Total drinks in the previous year had the highest sensitivity but lowest specificity.

###### AUDIT-C

No included studies that focused on young adults reported on test accuracy for using the AUDIT-C to screen for AUD.

###### AUDIT

Two studies reported a cutoff of 8 or higher,^84,^ ^120^ with sensitivity of 0.68 (95% CI, 0.60 to 0.75) and 0.82 (95% CI, 0.74 to 0.89) and specificity of 0.75 (95% CI, 0.68 to 0.81) and 0.72 (95% CI, 0.65 to 0.77), respectively (Figure 12, Appendix I Table 7). The optimal cutoff ranged from 6 or higher to 8 or higher in three studies reporting test accuracy for any cutoffs (sensitivity, 0.73 to 0.82 [95% CI range, 0.65 to 0.89]; specificity, 0.67 to 0.78 [95% CI range, 0.60 to 0.79]) (Figure 13).^84,^ ^95,^ ^120^

###### ASSIST

No studies in young adults reported on test accuracy for using the ASSIST to screen for AUD.

#### General Adults

##### Study and Population Characteristics

Eight good-quality^96,^ ^98,^ ^106,^ ^110,^ ^111,^ ^121,^ ^126,^ ^133^ and 19 fair-quality studies^93,^ ^97,^ ^99,^ ^103,^ ^104,^ ^107,^ ^108,^ ^112,^ ^113,^ ^115,^ ^117,^ ^122,^ ^124,^ ^125,^ ^128,^ ^129,^ ^132,^ ^134,^ ^136^ recruiting adults were included. Fifteen studies were conducted in the United States; the other 12 were conducted in Europe (one each in Switzerland/France, the Netherlands, United Kingdom, and Germany; two each in Finland and Italy; three in Spain) or Australia (k=1). Nine studies recruited from U.S. primary care. Mean age ranged from 26 to 52 years. One study recruited exclusively females^98^ and one study recruited exclusively males;^125^ otherwise, the proportion of female participants ranged from 20.3 to 74.8 percent. Three studies recruited participants from the VA.^98,^ ^104,^ ^125^ Six studies limited their recruitment or analysis to participants who the study categorized as current drinkers.^96,^ ^99,^ ^111,^ ^125,^ ^129,^ ^132^ Three studies recruited participants with diagnoses or symptoms of anxiety or depression,^96,^ ^97,^ ^122^ one recruited patients seeking evaluation for attention deficit hyperactivity disorder,^124^ and one recruited HIV- positive participants;^125^ two of these studies also recruited control participants who did not have the disease.^97,^ ^125^ Sample size ranged from 124 to 43,093 participants. Race/ethnicity was reported in 12 studies; 11 of the 12 studies were based in the United States. Six studies had a majority of white participants;^98,^ ^103,^ ^104,^ ^110,^ ^124,^ ^132^ six studies had higher proportions of other race/ethnic groups than whites, primarily black and Hispanic.^121,^ ^125,^ ^126,^ ^133,^ ^134,^ ^136^ While socioeconomic status was not widely reported, six U.S.-based studies recruited participants of lower socioeconomic status, as indicated by recruitment setting, income, employment, education, or combinations thereof.^99,^ ^117,^ ^121,^ ^126,^ ^134,^ ^136^

Eleven studies^93,^ ^108,^ ^115,^ ^122,^ ^125,^ ^126,^ ^128,^ ^129,^ ^132–134^ reported prevalence of unhealthy alcohol use, ranging from 7.9 to 53.2 percent; all but three of the 11 studies reported a prevalence of less than 33 percent.^108,^ ^122,^ ^132^ Across 16 studies,^96,^ ^99,^ ^104,^ ^106–108,^ ^110,^ ^111,^ ^117,^ ^121,^ ^124,^ ^126,^ ^132–134,^ ^136^ prevalence of AUD ranged from 7.7 to 43.8 percent; five of the 16 studies reported AUD prevalence greater than 20 percent.^99,^ ^108,^ ^110,^ ^117,^ ^132^ Twelve studies evaluated the test accuracy for identifying unhealthy alcohol use, 16 studies for identifying AUD, and 10 for identifying alcohol dependence. Nineteen studies assessed test accuracy of the AUDIT, 15 evaluated the AUDIT-C, 12 evaluated one- or two-item screeners, and one evaluated the ASSIST.^121^

The reference standard varied depending on the condition, but nearly all studies used a structured diagnostic interview, at times with TLFB, Short Inventory of Problems for alcohol, or the ASSIST. For AUD and alcohol dependence, all studies used a structured diagnostic interview, most frequently based on DSM-IV criteria. For unhealthy alcohol use, structured interview was often used in combination with the TLFB. In two studies,^93,^ ^122^ the target condition was exceeding recommended limits (ignoring AUD), and the reference standard was based on the TLFB only.

##### Full Spectrum of Unhealthy Alcohol Use

###### One- or Two-Item

Seven studies that recruited adults assessed the test accuracy of various one- or two-item screeners to screen for unhealthy alcohol use (Figure 1, Appendix I Table 10).^93,^ ^106,^ ^122,^ ^125,^ ^126,^ ^132,^ ^133^ Across these studies, sensitivity ranged from 0.65 to 0.90 (95% CI range, 0.58 to 0.91) and specificity ranged from 0.68 to 1.0 (95% CI range, 0.64 to 1.0) (n=48,211). Four studies^106,^ ^126,^ ^132,^ ^133^ with a total of 44,461 participants assessed the test accuracy of a question on heavy episodic drinking recommended by the NIAAA (5/4+ drinks) and reported sensitivity ranging from 0.73 to 0.88 (95% CI range, 0.65 to 0.90) and specificity ranging from 0.74 to 1.0 (95% CI range, 0.69 to 1.0) at the optimal cutoff. In general, the instruments defining a positive screen as drinking six or more drinks on one occasion had lower sensitivity and higher specificity than those using the standard of five/four or more drinks (for males/females). Five studies^93,^ ^112,^ ^126,^ ^132,^ ^133^ used a one- or two-item test to screen for persons exceeding recommended limits and reported sensitivity ranging from 0.75 to 0.93 (95% CI range, 0.61 to 0.96) and specificity ranging from 0.72 to 0.91 (95% CI range, 0.68 to 0.93) at the optimal cutoff. An additional study^125^ recruiting male HIV-positive patients and matched controls from the VA reported a sensitivity of 0.48 (95% CI, 0.39 to 0.57) and specificity of 0.94 (95% CI, 0.92 to 0.95) (Appendix H Figure 5, Appendix I Table 13).

###### AUDIT-C

Eight studies assessed the test accuracy of the AUDIT-C to screen for unhealthy alcohol use (Appendix I Table 10).^93,^ ^115,^ ^122,^ ^125,^ ^129,^ ^132–134^ In five studies reporting a cutoff of 3 or higher for females, sensitivity ranged from 0.73 to 0.97 (95% CI range, 0.62 to 0.99) and specificity ranged from 0.28 to 0.91 (95% CI range, 0.21 to 0.93) (Figure 2).^93,^ ^115,^ ^122,^ ^129,^ ^132–134^ In four of the five studies reporting a cutoff of 4 or higher for males, sensitivity ranged from 0.82 to 1.0 (95% CI range, 0.75 to 1.0) and specificity ranged from 0.34 to 0.89 (95% CI range, 0.25 to 0.92) (Figure 3).^93,^ ^115,^ ^122,^ ^129,^ ^132,^ ^134^ The remaining study recruited male patients from the VA and had much lower sensitivity at a cutoff of 4 or higher (0.63 [95% CI, 0.55 to 0.69], with corresponding specificity of 0.90 [95% CI, 0.87 to 0.92]).^125^ Optimal cutoffs ranged from 2 or higher to 6 or higher across eight studies; at times the optimal cutoffs differed by subgroup, with the optimal cutoff for females lower than the optimal cutoff for males (Appendix I Table 10). The most frequently reported optimal cutoffs were 4 or higher and 5 or higher. Across eight studies, sensitivity at the optimal cutoffs ranged from 0.74 to 0.92 (95% CI range, 0.62 to 0.98) and specificity ranged from 0.66 to 0.89 (95% CI range, 0.59 to 0.92) (Figure 4). One study that recruited male HIV-positive patients and matched controls from the VA reported a lower sensitivity for the optimal cutoff, at 0.63 (95% CI, 0.55 to 0.69), with corresponding specificity of 0.90 (95% CI, 0.87 to 0.92). Seven studies^106,^ ^112,^ ^113,^ ^125,^ ^129,^ ^132,^ ^133^ used the AUDIT-C to screen for persons exceeding recommended limits, with sensitivity ranging from 0.74 to 1.00 (95% CI range, 0.64 to 1.0) and specificity ranging from 0.77 to 0.92 (95% CI range, 0.73 to 0.92) at optimal cutoffs ranging from 3 to 5 (Appendix H Figure 6, Appendix I Table 13).

###### AUDIT

Nine studies reported the test accuracy of the AUDIT to screen for unhealthy alcohol use (Appendix I Table 10).^93,^ ^108,^ ^115,^ ^122,^ ^125,^ ^128,^ ^129,^ ^132,^ ^134^ At a cutoff of 8 or higher, seven studies reported sensitivity ranging from 0.38 to 0.73 (95% CI range, 0.33 to 0.84) and specificity ranging from 0.89 to 0.97 (95% CI, 0.83 to 0.98) (Figure 5).^93,^ ^115,^ ^122,^ ^125,^ ^129,^ ^132,^ ^134^ A cutoff of 8 or higher was optimal for only one subgroup in one study (males with mild depression).^122^ The optimal cutoffs ranged from 3 or higher to 11 or higher, with sensitivity ranging from 0.68 to 0.90 (95% CI range, 0.43 to 0.96) and specificity ranging from 0.75 to 0.96 (95% CI range, 0.63 to 0.98) (Figure 6). Eight studies had an optimal cutoff of 3 or higher to 5 for all participants or certain subgroups. For five studies,^93,^ ^108,^ ^115,^ ^122,^ ^134^ the optimal cutoff differed between males and females, with a lower optimal cutoff for females than for males. Six studies^93,^ ^110,^ ^112,^ ^125,^ ^129,^ ^132^ used the AUDIT to screen for persons exceeding recommended limits, with sensitivity ranging from 0.64 to 0.89 (95% CI range, 0.52 to 0.93) and specificity ranging from 0.67 to 0.95 (95% CI range, 0.59 to 0.97) at the optimal cutoff (ranging from 4 to 9) (Appendix H Figure 7, Appendix I Table 13).

Three studies recruiting U.S.-based primary care patients reported data on lower AUDIT cutoffs (≥3 to 5) for unhealthy use (Figure 7).^125,^ ^132,^ ^134^ At a cutoff of 3 or higher, two of the studies reported sensitivity of 0.86 (95% CI range, 0.77 to 0.91), with specificity ranging from 0.74 to 0.83 (95% CI range, 0.68 to 0.85). At a cutoff of 4 or higher, sensitivity ranged from 0.71 to 0.84 (95% CI range, 0.64 to 0.88) and specificity ranged from 0.77 to 0.90 (95% CI range, 0.73 to 0.91) across the three studies. At a cutoff of 5 or higher, sensitivity ranged from 0.64 to 0.71 (95% CI range, 0.57 to 0.77) and specificity ranged from 0.87 to 0.94 (95% CI range, 0.83 to 0.95).

###### ASSIST

No studies in general adults reported on test accuracy for using the ASSIST to screen for the full spectrum of unhealthy alcohol use.

##### AUD

###### One- or Two-Item

Four one- or two-item screening tests were used in seven studies to screen for AUD, with sensitivity ranging from 0.71 to 0.94 and specificity ranging from 0.60 to 0.91 (Figure 8, Appendix I Table 11). The question recommended by the NIAAA on heavy episodic drinking (5/4+ drinks) was used in six studies^96,^ ^106,^ ^126,^ ^132,^ ^133,^ ^136^ (n=44,244), with sensitivity at the optimal cutoffs ranging from 0.71 to 0.92 (95% CI range, 0.65 to 0.98) and specificity ranging from 0.60 to 0.91 (95% CI range, 0.55 to 0.95).

###### AUDIT-C

Six studies reported the test accuracy of the AUDIT-C to screen for AUD (Appendix I Table 11).^104,^ ^106,^ ^107,^ ^132–134^ In three^104,^ ^106,^ ^134^ studies reporting accuracy for a cutoff of 3 or higher for females, sensitivity ranged from 0.78 to 0.87 (95% CI range, 0.74 to 0.92) and specificity ranged from 0.69 to 0.85 (95% CI range, 0.65 to 0.75) (Figure 9). In three studies reporting test accuracy for a cutoff of 4 or higher for males, sensitivity ranged from 0.87 to 0.88 (95% CI range, 0.78 to 0.94) and specificity ranged from 0.63 to 0.75 (95% CI range, 0.62 to 0.80) (Figure 10).^106,^ ^107,^ ^132,^ ^134^ The optimal cutoff for six studies was 3 or higher or 4 or higher; one study had an optimal cutoff of 5 or higher for males.^104^ At the optimal cutoff, sensitivity ranged from 0.70 to 0.88 (95% CI range, 0.65 to 0.95) and specificity ranged from 0.70 to 0.85 (95% CI range, 0.66 to 0.87) (Figure 11).

###### AUDIT

Eight studies assessed test accuracy of the AUDIT to screen for AUD (Appendix I Table 11).^104,^ ^108,^ ^110,^ ^111,^ ^117,^ ^124,^ ^132,^ ^134^ At a cutoff of 8 or higher, six studies^104,^ ^111,^ ^117,^ ^124,^ ^132,^ ^134^ reported sensitivity ranging from 0.43 to 0.96 (95% CI range, 0.35 to 1.0) and specificity from 0.82 to 0.96 (95% CI range, 0.74 to 0.99) (Figure 12). Only one study had 8 or higher as the optimal cutoff.^117^ The optimal cutoffs ranged from 5 or higher to 10 or higher (seven studies reported optimal cutoffs of ≥5 to 7), with sensitivity from 0.48 to 0.96 (95% CI range, 0.35 to 1.0) and specificity from 0.34 to 0.96 (95% CI range, 0.28 to 0.99) (Figure 13).

Two studies recruiting participants from U.S. primary care reported test accuracy at lower cutoffs (≥4 and ≥5) (Figure 7, Appendix I Table 11).^132,^ ^134^ At a cutoff of 4 or higher, sensitivity was 0.83 (95% CI, 0.76 to 0.88), with corresponding specificity of 0.67 (95% CI, 0.63 to 0.71).^132^ At a cutoff of 5 or higher, sensitivity was 0.72 (95% CI, 0.65 to 0.79) and 0.80 (95% CI, 0.73 to 0.86), with corresponding specificity of 0.79 (95% CI, 0.75 to 0.82) and 0.88 (95% CI, 0.86 to 0.90).^132,^ ^134^ In contrast, sensitivity was much lower in these studies using the cutoff of 8 or higher (0.43 [95% CI, 0.35 to 0.51]^132^ and 0.55 [95% CI, 0.47 to 0.63]^134^).

###### ASSIST

One study^121^ reported the test accuracy of the ASSIST to screen for AUD (Appendix I Table 11). The optimal cutoff for females was 7 or higher, with sensitivity of 0.86 (95% CI, 0.42 to 0.97) and specificity of 0.83 (95% CI, 0.77 to 0.88). The optimal cutoff for males was 13 or higher, with sensitivity of 0.80 (95% CI, 0.64 to 0.91) and specificity of 0.95 (95% CI, 0.90 to 0.98).

#### Older Adults

##### Study and Population Characteristics

Three good-quality studies recruited older adults from the community, one in Finland (n=517)^94^ and one in the United States (n=8,666).^106,^ ^139^ The U.S.-based study recruited all adults and presented test accuracy results for an older adult subgroup.^106,^ ^139^ In the Finnish study, the mean age was 69 years, half of the participants were female, and race/ethnicity and socioeconomic status were not reported. Subgroup-specific population characteristics were not reported for the U.S.-based study.^106,^ ^139^ These studies assessed the accuracy of the AUDIT, AUDIT-C, and several one- or two-item screeners to screen for unhealthy alcohol use,^94,^ ^106,^ ^139^ AUD,^106,^ ^139^ and alcohol dependence.^94^ The TLFB was the reference standard for the Finnish study, classifying 23 percent of participants with unhealthy alcohol use; the U.S.-based study^106,^ ^139^ used a structured clinical interview. An additional study, conducted in Spain, assessed only the test accuracy of the AUDIT and AUDIT-C to screen older adults for exceeding recommended levels of alcohol intake.^113^

##### Full Spectrum of Unhealthy Alcohol Use

###### One- or Two-Item

Two studies^94,^ ^106^ reported test accuracy for a variety of one- or two-item screening questions, with sensitivity ranging from 0.64 to 0.97 (95% CI range, 0.61 to 0.99) and specificity ranging from 0.70 to 1.0 (95% CI range, 0.65 to 1.0) (Figure 1, Appendix I Table 15). The U.S.-based study reported test accuracy for the NIAAA-recommended question (5/4+ drinks) to assess heavy episodic drinking, with sensitivity of 0.64 (95% CI, 0.61 to 0.67) and specificity of 1.0 (95% CI, 1.0 to 1.0).^106,^ ^139^

###### AUDIT-C

At the optimal cutoff of 4 or higher in the Finnish study, sensitivity was 0.94 (95% CI, 0.88 to 0.97) and specificity was 0.80 (95% CI, 0.76 to 0.84) (Figure 4, Appendix I Table 15).^94^ Two studies^106,^ ^113^ reported test accuracy to detect persons exceeding recommended limits, with sensitivity ranging from 0.93 to 10.0 (95% CI range, 0.91 to 1.0) and specificity ranging from 0.81 to 0.85 (95% CI range, 0.80 to 0.86) at optimal cutoffs of 3 or higher and 4 or higher (Appendix H Figure 6, Appendix I Table 13).

###### AUDIT

The sensitivity and specificity at the cutoff of 8 or higher was 0.48 (95% CI, 0.39 to 0.57) and 0.97 (95% CI, 0.95 to 0.98), respectively, in the Finnish study (Figure 5, Appendix I Table 14). The optimal cutoff was 5 or higher, with sensitivity of 0.86 (95% CI, 0.78 to 0.91) and specificity of 0.87 (95% CI, 0.83 to 0.90) (Figure 6). At the optimal cutoff of 8 or higher, one study^113^ reported a sensitivity of 0.67 (95% CI, 0.64 to 0.70) and specificity of 0.95 (95% CI, 0.95 to 0.96) to detect persons exceeding recommended limits (Appendix H Figure 7, Appendix I Table 13).

###### ASSIST

No studies in older adults reported on test accuracy for using the ASSIST to screen for the full spectrum of unhealthy alcohol use.

###### CARET

No studies in older adults reported on test accuracy for using the CARET to screen for the full spectrum of unhealthy alcohol use.

##### AUD

###### One- or Two-Item

No studies in older adults reported on test accuracy for using a one- or two-item screening test to screen for AUD.

###### AUDIT-C

The U.S.-based study reported the test accuracy of the AUDIT-C to screen for AUD in adults age 65 years or older who had drunk alcohol in the previous year. At the optimal cutoff of 4 or higher, sensitivity was 0.76 (95% CI, 0.67 to 0.83) and specificity was 0.74 (95% CI, 0.72 to 0.75) (Figure 11, Appendix I Table 16).

###### AUDIT

No studies in older adults reported on test accuracy for using the AUDIT to screen for AUD.

###### ASSIST

No studies in older adults reported on test accuracy for using the ASSIST to screen for AUD.

###### CARET

No studies in older adults reported on test accuracy for using the CARET to screen for AUD.

#### Pregnant Women

Two fair-quality studies^100,^ ^135^ and one good-quality study^106^ recruited pregnant women. Two studies were set in the United States, with one recruiting American Indian women (or women carrying American Indian babies) at a mean of 15 weeks’ gestation attending prenatal appointments^100^ and the other recruiting pregnant past-year drinkers from the community through a large epidemiologic survey.^106^ The third study was set in Argentina and recruited postpartum women within 48 hours of delivery.^135^ Mean age was 24^135^ and 26^100^ years in two studies; the third study did not report maternal age.^106^ In one study, based on a structured interview and medical records, 53 percent of women used alcohol during their pregnancy.^100^ The other study used a structured interview to identify the target conditions, reporting 5.5 percent with AUD and 3.5 percent with alcohol dependence.^106^ The study in Argentina did not report prevalence.^135^

##### Alcohol Use

###### One- or Two-Item

The study in American Indian women reported the test accuracy of a quantity-frequency question to screen for any alcohol use during pregnancy (Appendix I Table 18). At the optimal cutoff, sensitivity was 0.77 (95% CI, 0.68 to 0.83) and specificity was 0.93 (95% CI, 0.86 to 0.96).^100^

###### Other Tools

No studies in pregnant women reported on test accuracy for using the AUDIT-C, AUDIT, ASSIST, TWEAK, or T-ACE to screen for alcohol use.

##### Full Spectrum of Unhealthy Alcohol Use

No studies in pregnant women reported on test accuracy for using any screening test to screen for unhealthy alcohol use.

##### AUD

###### One- or Two-Item

No studies in pregnant women reported on test accuracy for using a one- or two-item screening test to screen for AUD.

###### AUDIT-C

Two studies reported the test accuracy of the AUDIT-C to screen for AUD.^106,^ ^135^ At a cutoff of 3 or higher, also the optimal cutoff in both studies, sensitivity ranged from 0.90 to 0.96 (95% CI range, 0.69 to 0.99) and specificity ranged from 0.71 to 0.79 (95% CI range, 0.65 to 0.82) (Appendix I Table 19).

###### AUDIT

In one study at the optimal cutoff of 4 or higher, sensitivity was 0.87 (95% CI, 0.74 to 0.94) and specificity was 0.86 (95% CI, 0.83 to 0.89).^135^

###### T-ACE

In one study at the optimal cutoff of 2 or higher, sensitivity was 0.96 (95% CI, 0.86 to 0.99) and specificity was 0.76 (95% CI, 0.72 to 0.79).^135^

###### TWEAK

In one study at the optimal cutoff of 2 or higher, sensitivity was 0.96 (95% CI, 0.86 to 0.99) and specificity was 0.77 (95% CI, 0.73 to 0.80).^135^

###### ASSIST

No studies in pregnant women reported on test accuracy for using the ASSIST to screen for AUD.

## KQ3 What Are the Harms of Screening for Unhealthy Alcohol Use in Adolescents and Adults, Including Pregnant Women?

Hypothesized possible harms included stigma, labeling, discrimination, privacy concerns, and interference with the patient-provider relationship. In addition, there may be legal concerns for pregnant women in some states. We found no trials that examined the harms of screening for unhealthy alcohol use.

## KQ4a Do Counseling Interventions to Reduce Unhealthy Alcohol Use, With or Without Referral, Reduce Unhealthy Alcohol Use or Improve Other Risky Behaviors in Screen-Detected Persons?

## KQ4b Do Counseling Interventions to Reduce Unhealthy Alcohol Use, With or Without Referral, Reduce Morbidity or Mortality or Improve Other Health, Social, or Legal Outcomes in Screen-Detected Persons?

## KQ5 What Are the Harms of Interventions to Reduce Unhealthy Alcohol Use in Screen-Detected Persons?

### Included Trials

We included 68 trials (in 102 publications)^148–249^ (n=36,528) that addressed the effect of a counseling intervention on alcohol use or health, social, or legal outcomes in a screen-detected population (Table 7, Appendix I Table 21). Two of the trials targeted adolescents,^210,^ ^215^ 22 targeted college-aged or young adults,^160–162,^ ^170,^ ^189,^ ^192,^ ^194–201,^ ^205,^ ^211,^ ^220,^ ^223,^ ^225,^ ^226,^ ^239^ 29 addressed general adult populations,^149,^ ^152,^ ^153,^ ^163,^ ^165,^ ^169,^ ^171,^ ^172,^ ^174,^ ^175,^ ^184–186,^ ^188,^ ^190,^ ^193,^ ^206,^ ^208,^ ^209,^ ^218,^ ^224,^ ^228,^ ^231,^ ^233,^ ^234,^ ^240,^ ^242^ four focused on older adults,^157,^ ^176,^ ^183,^ ^230^ and 11 targeted pregnant^168,^ ^181,^ ^191,^ ^202,^ ^203,^ ^217,^ ^221,^ ^222,^ ^235^ or postpartum^158,^ ^212^ women. Tables 8 and 9 summarize study and population characteristics for these trials. Most trials were conducted in the United States (41/68 [60%]) and in primary care settings (42/68 [62%]). We rated 10 of the trials as good quality^153,^ ^161,^ ^168,^ ^183,^ ^205,^ ^210,^ ^220,^ ^226,^ ^230,^ ^234^ and the remaining were fair quality; 28 trials were excluded due to poor quality. Nineteen of the trials (28%) were included in the previous review.

Table 7 Trial and Population Characteristics for KQ4, by Population

Target population | Author, year Study name | QR | Country | n rand | Brief population description | Mean age, yrs | Female, % | Race/ethnicity, % | SES variables | Outcomes reported
Adolescents | Haug, 2016^210^ | Good | SWL | 469 | High school students, ages 16-19 years (only abstracted medium- and high-risk subgroups) | 16.8 | 52.6 | -- | Secondary school: 89.7% Technical school or university: 6.3% | Beh
Adolescents | Mason, 2015^215^ | Fair | US | 119 | Adolescents, ages 14-18 years | 16.4 | 71 | Black: 84.0 Other: 16.0 | -- | Beh
Young adults | Bertholet, 2015^220^ | Good | SWL | 737 | Men, age 21 years | 20.8 | 0 | -- | -- | Beh, Health/Other
Young adults | Carey, 2006^189^ | Fair | US | 509 | College students ages 18-25 years | 19.2 | 65 | White: 89.0 | -- | Beh, Health/Other
Young adults | Collins, 2014^223^ | Fair | US | 724 | College students age ≥18 years | 20.8 | 56 | White: 67.1 Black: 1.0 Asian: 18.5 AI/AN: 0.6 Hisp: 6.5 Other: 3.3 | -- | Beh, Health/Other
Young adults | Daeppen, 2011^192^ | Fair | SWL | 217 | Men, age 20 years | 19.9 | 0 | -- | Some postsecondary education: 57.2% | Beh
Young adults | Fleming, 2010^160^ CHIPS | Fair | US, CAN | 986 | College students | 21 | 50.9 | White: 90.7 | -- | Beh, Health/Other
Young adults | Johnsson, 2006^194^ | Fair | SWE | 177 | Incoming university students | 21 | 24.8 | -- | -- | Beh
Young adults | Kypri, 2004^161^ | Good | NZL | 104 | College students ages 17-26 years | 20 | 50 | -- | -- | Beh, Health/Other
Young adults | Kypri, 2008^162^ | Fair | NZL | 576 | College students, ages 17-29 years | 20.1 | 52 | -- | -- | Beh
Young adults | Kypri, 2009^195^ | Fair | AUS | 2435 | College students ages 17-24 years | 19.7 | 45.3 | -- | -- | Beh
Young adults | LaBrie, 2009^196^ | Fair | US | 285 | First-year female college students | 17.9 | 100 | White: 57.5 Black: 5.3 Asian: 10.5 Hisp: 13.0 Other: 13.7 | -- | Beh
Young adults | LaBrie, 2013^227^ | Fair | US | 554 | College students, age 18-24 years | 19.9 | 56.7 | White: 75.7 Asian: 24.3 | -- | Beh, Health/Other
Young adults | Larimer, 2007^197^ | Fair | US | 1488 | College students | NR | 70.8 | White: 80.8 Black: 0.8 Asian: 7.8 Hisp: 3.1 Other: 7.5 | -- | Beh, Health/Other, Harms
Young adults | Leeman, 2016^211^ | Fair | US | 208 | College students, age 18-24 years | 19.8 | 62.5 | White: 68.3 Black: 16.8 Hisp: 4.3 Other: 5.6 | -- | Beh
Young adults | Lewis, 2014^225^ | Fair | US | 359 | College students, ages 18-25 years | 20.1 | 57.6 | White: 70.0 Asian: 12.5 Other: 16.2 | -- | Beh, Health/Other
Young adults | Marlatt, 1998^198^ | Fair | US | 348 | Incoming college students, age ≤19 years | NR | 54 | White: 84.0 | -- | Beh, Health/Other
Young adults | Martens, 2010^199^ | Fair | US | 263 | College athletes | 20.0 | 76 | White: 85.5 Black: 1.9 Asian: 5.0 Hisp: 1.9 Other: 5.7 | -- | Health/Other
Young adults | Neighbors, 2004^200^ | Fair | US | 252 | College students | 18.5 | 58.7 | White: 79.5 Asian: 13.7 Other: 6.8 | -- | Beh, Health/Other
Young adults | Neighbors, 2010^201^ | Fair | US | 818 | Incoming college freshman students | 18.7 | 57.6 | White: 65.3 Black: 1.5 Asian: 24.2 AI/AN: 0.5 Hisp: 4.2 Other: 4.4 | -- | Beh, Harms
Young adults | Neighbors, 2016^239^ | Fair | US | 623 | College students, ages 18-26 years | 20.6 | 53.2 | White: 61.7 Black: 5.4 Asian: 16.3 AI/AN: 1.0 Hisp: 21.3 Other: 15.6 | -- | Beh, Health/Other
Young adults | Schaus, 2009^170^ | Fair | US | 363 | College students seeking care at university health services, age ≥18 years | 20.6 | 52.1 | White: 77.4 Black: 4.7 Asian: 2.8 AI/AN: 0.3 Hisp: 11.3 Other: 3.0 | -- | Beh, Health
Young adults | Turrisi, 2009^205^ | Good | US | 1275 | Former high school athletes beginning college | 17.9 | 55.6 | White: 79.8 Black: 2.0 Asian: 10.6 AI/AN: 0.2 Hisp: 4.5 Other: 6.9 | -- | Beh, Health/Other
Young adults | Voogt, 2014^226^ What Do You Drink (WDYD) | Good | NLD | 913 | College students, ages 18-24 years | 20.8 | 39.7 | -- | -- | Beh
Adults | Aalto, 2000^206^ Lahti Project | Fair | FIN | 265 | Adults, ages 20-60 years | 42 | 29.4 | -- | Comprehensive school: 48.7% Vocational school: 26.0% College: 21.1% | Beh, Health/Other
Adults | Bischof, 2008^149^ | Fair | DEU | 408 | Adults, ages 18-64 years | 36.5 | 31.9 | -- | Years of schooling (mean): 10.5 | Beh, Health/Other, Harms
Adults | Burge, 1997^188^ | Fair | US | 242 | Mexican American adults attending primary care appointment, age ≥18 years | 39.4 | 25 | White: 6.1 Black: 7.2 Hisp: 86.7 | Mean education: 8.8 years Uninsured: 77% | Beh, Health/Other
Adults | Butler, 2013^242^ PRE-EMPT | Fair | GBR | 1827 | Adults, age ≥18 years | 50.9 | 62 | -- | Managerial and professional occupations: 43.0% | Beh
Adults | Chang, 2011^190^ | Fair | US | 511 | Women with medical diagnoses potentially exacerbated by risky drinking | 45.1 | 100 | White: 75.5 Black: 21.8 Asian: 2.0 Hisp: 5.4 | ≥College degree: 62.2% | Beh
Adults | Crawford, 2014^185^ | Fair | GBR | 802 | Adults attending sexual health clinic, age ≥19 years | 26.7 | 53.9 | White: 77.3 Black: 13.0 Asian: 3.6 Other: 6.0 | | Beh, Health/Other
Adults | Cunningham, 2012^231^ | Fair | CAN | 1767 | Adults, age ≥19 years | 40.7 | 33.6 | -- | Postsecondary education: 74.2% | Beh
Adults | Curry, 2003^152^ | Fair | US | 307 | Adults, age ≥18 years | 46.9 | 35.5 | White: 80.0 | Post-high school education: 91.0% Annual income >$35,000: 67.5% Employed full- or part- time: 80.5% | Beh
Adults | Drummond, 2009^208^ | Fair | GBR | 112 | Males attending a primary care appointment, age ≥18 years | 41.8 | 0 | -- | -- | Beh, Health/Other
Adults | Emmen, 2005^193^ | Fair | NLD | 123 | Adults attending primary care appointment, age ≥18 years | 49 | 24.4 | -- | Some post-secondary education: 47.2% | Beh, Health/Other (liver only)
Adults | Fleming, 1997^153^ TrEAT (Trial for Early Alcohol Treatment) | Good | US | 774 | Adults attending appointment with PCP, ages 18-65 years | NR | 37.7 | White: 91.6 Black: 4.2 Hisp: 1.3 Other: 2.9 | Some college: 38.6% ≥College degree: 19.0% | Beh, Health/Other
Adults | Hansen, 2012^234^ | Good | DNK | 1380 | Adults participating in epidemiologic household survey | 57.9 | 44.9 | -- | 15+ years education: 51.7% | Beh
Adults | Heather, 1987^209^ DRAMS (Drink Reasonably And Moderately with Self-control) | Fair | GBR | 104 | Adults attending GP appointment, ages 18-65 years | 36.4 | 25 | -- | | Beh, Health/Other
Adults | Helstrom, 2014^240^ | Fair | US | 139 | Veterans attending PCP appointment, ages 23-83 years | 57.2 | 2 | White: 55.0 | Financially comfortable (“enough money to get by”): 79.9% | Beh, Health/Other
Adults | Hilbink, 2012^233^ | Fair | NLD | 712 | Adults presenting to primary care, age ≥18 years | 47.5 | 30.3 | -- | High education level: 32.7% | Beh
Adults | Kaner, 2013^186^ Screening and Intervention Program for Sensible Drinking (SIPS) | Fair | GBR | 756 | Adults attending appointment with GP, age ≥18 years | 44.5 | 37.8 | White: 91.7 | College degree or equivalent: 33.8% | Beh
Adults | Maisto, 2001^163^ | Fair | US | 301 | Adults attending appointment with PCP, age ≥21 years | 45.6 | 30.2 | White: 76.7 Black: 21.9 AI/AN: 0.3 Hisp: 0.3 Other: 0.7 | Post-high school education: 56.8% | Beh
Adults | Ockene, 1999^165^ | Fair | US | 530 | Adults attending a primary care appointment, ages 21-70 years | 43.9 | 35.3 | White: 82.6 Other: 17.4 | ≥High school graduate +/- some college: 47.0% ≥College graduate: 37.2% | Beh
Adults | Richmond, 1995^175^ | Fair | AUS | 285 | Adults attending appointment with GP, ages 18-70 years | 37.3 | 44.3 | -- | -- | Beh
Adults | Rose, 2017^245^ | Fair | US | 1855 | Adults scheduled for a routine primary care visit, age ≥18 years | NR | 52.5 | White: 95.0 | ≤High school/GED: 31.5% Some college: 10.5% ≥BA: 59.0% | Beh
Adults | Rubio, 2010^168^ | Good | ESP | 752 | Adults attending appointment with PCP, ages 18-65 years | NR | 34.7 | -- | Some college: 38.4% ≥College degree: 3.7% | Beh
Adults | Watkins, 2017^246^ | Fair | US | 397 | Adults attending a primary care visit at FQHC, age ≥18 years | 42 | 20.4 | White: 43.8 Black: 13.3 Asian: 1.3 Hisp: 31.0 Other: 40.3 | <High school: 27.9% High school graduate/GED: 31.0% >High school: 41.1% | Beh, Health/Other
Adults | Saitz, 2003^169^ | Fair | US | 312 | Adults attending primary care appointment | 43 | 36.5 | White: 19.1 Black: 56.1 Hisp: 16.5 | High school education: 63.4% Unemployed: 40.0% | Beh
Adults | Schulz, 2013^228^ | Fair | DEU | 448 | Adults, age ≥18 years | 41.7 | 43.5 | -- | High education level: 34.0% Monthly income ≥€2001: 39.7 | Beh
Adults | Scott, 1990^171^ | Fair | GBR | 226 | Adults, ages 17-69 years | 44.7 | 31.9 | -- | -- | Beh, Health/Other
Adults | Senft, 1997^172^ | Fair | US | 516 | Adults attending primary care appointment, age ≥21 years | 42.5 | 29.5 | White: 82.0 Other: 18.0 | ≥Some college: 59.5% | Beh, Health/Other
Adults | Upshur, 2015^218^ Project RENEWAL | Fair | US | 82 | Homeless women attending a PCP appointment, age ≥18 years | 45.4 | 100 | White: 32.9 Black: 41.5 Other: 25.6 | Lived in shelter or on street in past 3 months: 70.7% Monthly income primarily from SSI, SSDI, and food stamps: $850 | Beh, Health/Other
Adults | Wallace, 1988^174^ | Fair | GBR | 909 | Adult primary care patients, ages 17-69 years | 42 | 29.4 | -- | -- | Beh, Health/Other
Adults | Wilson, 2014^224^ | Fair | GBR | 102 | Adults with hypertension, age ≥18 years | 64 | 12 | -- | Unemployed: 74.4% | Beh, Health/Other (BP only)
Older adults | Ettner, 2014^183^ Project SHARE | Good | US | 1186 | Primary care patients, age ≥60 years | 71 | 34.3 | White: 97.3 Black: 0.3 Asian: 0.9 AI/AN: 1.5 Hisp: 5.9 | Some college: 27% ≥College degree: 59% Income ≥$100,000: 30% | Beh, Health/Other
Older adults | Fleming, 1999^157^ Project GOAL (Guiding Older Adult Lifestyles) | Fair | US | 158 | Older adults attending primary care appointment, age ≥65 years | NR | 33.5 | -- | -- | Beh, Health/Other
Older adults | Moore, 2010^176^ Healthy Living As You Age (HLAYA) | Fair | US | 631 | Adults attending appointment with PCP, age ≥55 years | 68.4 | 29 | White: 87.3 Hisp: 9.2 Other: 3.3 | Some college: 30.7% ≥College degree: 45.8% | Beh, Health/Other
Older adults | Watson, 2013^230^ | Good | GBR | 529 | Older adults attending primary care appointments, age ≥55 years | 62.8 | 19.7 | -- | College degree or equivalent: 41.8% Local authority/public housing: 14.8% | Beh, Health/Other, Harms
Pregnant women | Chang, 1999^181^ | Fair | US | 250 | Pregnant women attending their first prenatal appointment (mean, 16 weeks’ gestation), ages 18-43 years | 30.7 | 100 | White: 78.0 Black: 14.0 Asian: 2.0 Hisp: 6.0 | Some college: 29% ≥College degree: 56% Married: 74% | Beh, Health/Other
Pregnant women | Chang, 2005^191^ | Fair | US | 304 | Pregnant women attending a prenatal appointment (mean, 12 weeks’ gestation) | NR | 100 | White: 78.6 Black: 7.6 Other: 13.8 | Median education: 16 years Median annual income for home ZIP code: $55,357 Married/in a committed relationship: 80.5% | Beh
Pregnant women | O’Connor, 2007^202^ | Fair | US | 345 | Pregnant women attending a prenatal appointment at a WIC clinic (mean, 18 weeks’ gestation) | 28.1 | 100 | White: 7.9 Black: 18.9 Hisp: 34.5 Other: 4.3 | Mean education: 11.4 years Annual income ≤$15,000: 67.2% | Beh, Health/Other
Pregnant women | Ondersma, 2015^217^ | Fair | US | 48 | Pregnant women, seeking services at a prenatal care clinic (mean, 12 weeks’ gestation), age ≥18 years | NR | 100 | Black: 81.3 | ≥High school: 66.7% Any public assistance: 81.3% Married: 20.8% | Beh, Health/Other, Harms
Pregnant women | Osterman, 2014^221^ | Fair | US | 122 | Pregnant women attending prenatal appointment (mean, 24 weeks’ gestation), ages 18-44 years | 25.4 | 100 | White: 30.3 Black: 58.2 Hisp: 3.3 Other: 5.7 | Some college: 41.8% ≥College degree: 3.3% Annual income ≤$15,000: 69.7% Married: 14.8% | Beh, Health/Other
Pregnant women | Reynolds, 1995^203^ | Fair | US | 78 | Pregnant women attending prenatal appointment (mean, 12 weeks’ gestation) | 22.4 | 100 | White: 33.3 Black: 66.7 | Income: <$5,000: 58.3% <$10,000: 88.0% | Beh
Pregnant women | Rubio, 2014^184^ | Fair | US | 330 | Pregnant women attending their 1st or 2nd obstetric appointment (mean, 10 weeks’ gestation), age ≥18 years | 23.8 | 100 | White: 53.6 Black: 43.0 Other: 3.3 | Some postsecondary education: 26.5% ≥College degree: 10.2% Medicaid: 89.0% | Beh, Health/Other
Pregnant women | Tzilos, 2011^235^ | Fair | US | 50 | Pregnant women attending a prenatal care appointment (mean, 25 weeks’ gestation), ages 18-45 years | 25.6 | 100 | White: 16.0 Black: 82.0 Hisp: 2.0 | Education level: 0-8 grades: 10.0% 9-11 grades: 48.0% High school graduate/GED: 30.0% Some college: 12.0% WIC food assistance: 72.0% FIA assistance: 44.0% | Beh, Health/Other
Pregnant women | van der Wulp, 2014^222^ | Fair | NLD | 393 | Pregnant women (mean, 8 weeks’ gestation), age ≥18 years | 32.6 | 100 | -- | High education level: 66.2% High income: 33.9% Steady partner: 56.7% | Beh
Postpartum women | Fleming, 2008^158^ | Fair | US | 235 | Postpartum women (mean, 6.4 weeks postpartum) attending appointments for postpartum care, age ≥18 years | NR | 100 | White: 81.7 Black: 6.8 Asian: 0.9 AI/AN: 7.2 Hisp: 2.5 Other: 0.9 | Some college: 31.5% ≥College degree: 31.5% Working full- or part time: 19.5% Married: 60.8% | Beh
Postpartum women | Ondersma, 2016^212^ | Fair | US | 123 | Postpartum women in postdelivery recovery, age ≥18 years | 27.1 | 100 | White: 4.1 Black: 87.0 Other: 9.0 | ≥High school: 74.8% Receipt of food assistance: 74.8% | Beh

Abbreviations: AI/AN = American Indian/Alaska Native; AUS = Australia; Beh = behavioral; CAN = Canada; DEU = Germany; DNK = Denmark; FIN = Finland; FQHC = federally qualified health clinic; GBR = Great Britain; GP = general practitioner; Hisp = Hispanic; KQ = key question; NLD = Netherlands; NZL = New Zealand; PCP = primary care provider; QR = quality rating; rand = randomized; SES = socioeconomic status; SSDI = Social Security Disability Insurance; SSI = Supplemental Security Income; SWE = Sweden; SWL = Switzerland; US = United States; yrs = years.

Table 8 Summary Study Characteristics for Key Questions 4 and 5

Population | No. studies | No. randomized | No. (%) good quality | No. (%) conducted in U.S. | Other countries represented | No. (%) in primary care | Other settings | Median % followup (range) | No. (%) in previous review
All populations | 68 | 36,528 | 10 (15) | 41 (60) | | 42 (62) | | 82 (59-100) | 19 (28)
Adolescents | 2 | 588 | 1 (50) | 1 (50) | SWL | 1 (50) | High school | 96 (93-98) | 0 (0)
Adults (nonpregnant/postpartum) | 55 | 33,662 | 9 (16) | 30 (55) | | 32 (58) | | 82 (59-96) | 17 (31)
Young adults | 22 | 14,214 | 4 (18) | 15 (68.2) | AUS, CAN, NLD, NZL, SWE, SWL | 4 (18) | University (k=16), military recruitment center (k=2) | 84 (65-90) | 4 (18)
Adults | 29 | 16,944 | 3 (10) | 12 (41) | AUS, CAN, DEU, DNK, ESP, FIN, GBR, NLD | 24 (83) | Other medical (k=2), research registry (k=1), epidemiologic household surveys (k=2) | 77 (59-96) | 11 (38)
Older adults | 4 | 2504 | 2 (50) | 3 (75) | GBR | 4 (100) | -- | 88 (83-92) | 2 (50)
Pregnant/postpartum | 11 | 2278 | 0 | 10 (91) | | 9 (82) | | 81 (63-100) | 2 (18)
Pregnant women | 9 | 1920 | 0 | 8 (89) | NLD | 8 (89) | -- | 81 (63-100) | 1 (11)
Postpartum women | 2 | 358 | 0 | 2 (100) | -- | 1 (50) | Postpartum recovery | 79 (70-88) | 1 (50)

Abbreviations: AUS = Australia; CAN = Canada; DEU = Germany; DNK = Denmark; ESP = Spain; FIN = Finland; GBR = Great Britain; NLD = Netherlands; No. = number; NZL = New Zealand; RCT = randomized controlled trial; SWE = Sweden; SWL = Switzerland; WIC = Women, Infants, and Children.

Table 9 Summary Population Characteristics for Key Questions 4 and 5

Population | No. studies | Average age^*^ | % Female^*^ | % White^*^,^†^ (no. studies reporting) | % Black^*^,^†^ (no. studies reporting) | % Asian^*^,^†^ (no. studies reporting) | % American Indian/Alaska Native^*^,^†^ (no. studies reporting) | % Hispanic^*^,^†^ (no. studies reporting) | No. (%) studies majority nonwhite^‡^ | No. (%) studies majority low SES^§^ | Average baseline alcohol use^*^ (no. studies reporting)
All populations | 68 | 35.0 | 48.8 | 74.7 (37) | 11.4 (28) | 10.3 (16) | 1.0 (9) | 9.7 (22) | 11 (16) | 12 (18) | Drinks/week: 16 (44) HUE/week: 1.8 (16)
Adolescents | 2 | 16.7 | 56.3 | NR | 84 (1) | NR | NR | NR | 1 (50) | 0 | Drinks/week: 12 (1) HUE/week: 0.4 (1)
Adults (nonpregnant/postpartum) | 55 | 35.5 | 44.8 | 77.6 (28) | 6.7 (17) | 10.7 (14) | 0.7 (8) | 9.2 (17) | 4 (7) | 5 (9) | Drinks/week: 16 (40) HUE/week: 2.0 (14)
Young adults | 22 | 19.8 | 51.5 | 75.0 (14) | 2.7 (9) | 13.6 (11) | 0.5 (5) | 6.8 (9) | 0 | 0 | Drinks/week: 11 (17) HUE/week: 2.6 (8)
Adults | 29 | 44.7 | 42.1 | 76.2 (12) | 18.7 (7) | 1.5 (2) | 0.9 (2) | 16.7 (6) | 4 (14) | 5 (17) | Drinks/week: 22 (20) HUE/week: 1.0 (5)
Older adults | 4 | 68.5 | 29.8 | 93.8 (2) | 0.3 (1) | 0.9 (1) | 1.5 (1) | 7.0 (2) | 0 | 0 | Drinks/week: 14 (3) HUE/week: 1.0 (1)
Pregnant/postpartum | 11 | 28.1 | 100 | 49.3 (9) | 31.4 (10) | 1.5 (2) | 7.2 (1) | 14.5 (5) | 6 (55) | 7 (64) | Drinks/week: 6 (3) HUE/week: 0.8 (1)
Pregnant women | 9 | 28.2 | 100 | 47.9 (7) | 30.7 (8) | 2.0 (1) | NR | 18.1 (4) | 5 (56) | 6 (67) | Drinks/week: 1.8 (2) HUE/week: NR (0)
Postpartum women | 2 | 27.1 | 100 | 55.0 (2) | 34.4 (2) | 0.9 (1) | 7.2 (1) | 2.5 (1) | 1 (50) | 1 (50) | Drinks/week: 8 (1) HUE/week: 0.8 (1)

* Weighted by n randomized.

† Among studies conducted in the U.S. (k=39).

‡ Assuming studies not reporting race/ethnicity were majority white.

§ Assuming studies not reporting SES are not majority low SES; low SES defined as >50% uninsured, Medicaid, annual income <$15,000, or on public assistance or >20% homeless.

Abbreviations: HUE = heavy use episodes; No. = number; RCT = randomized controlled trial; SES = socioeconomic status.

All trials conducted outreach to potential participants with a request to complete a screening instrument, although some studies also allowed participants to self-identify or accepted referrals from medical providers or service agencies. Most trials were limited to participants who reported a prespecified level of alcohol use (most commonly, either more than 7 (female) or 14 (male) drinks per week on average, or drinking 4 (female) or 5 (male) or more drinks on a single occasion), or scored above a predetermined cutoff on a screening instrument such as the AUDIT. Two trials did not restrict participants based on alcohol use, but reported subgroup analyses among unhealthy users.^192,^ ^210^ Four trials in young adults included everyone screened regardless of screening results, rather than limiting their sample to unhealthy users,^196,^ ^197,^ ^199,^ ^205^ and did not report subgroup analyses among those who met criteria for unhealthy alcohol use. We included these studies because the average consumption was in the high-risk use range, indicating an alcohol use reduction intervention was appropriate for at least half the sample. For example, two of the trials targeting incoming freshmen (average age, 18 years) reported baseline weekly alcohol use of 3.5^196^ and 7^205^ drinks per week, along with an average of one heavy use episode every 2 weeks^196^ or an average of 2.2 alcohol-related problems.^205^ All four of these trials’ interventions were very consistent with other trials’ interventions in this age group.

### Interventions

Information about the interventions can be found in Table 10 and Appendix I Tables 22 and 23. Most interventions involved one to two sessions (90% involved ≤4 sessions), with a median of 30 minutes of contact time (88% involved ≤2 hours of contact). Almost all interventions involved at least general feedback, such as how the participant’s drinking fit with recommended limits and how to reduce alcohol use. Many interventions, particularly those in primary care settings, used an SBIRT approach, consistent with those recommended by several health organizations (Table 3). The most commonly reported intervention element was the use of personalized normative feedback sessions, in which participants were shown how their alcohol use compares to others; this technique was used in more than half of the included trials and almost all trials in younger adults. Motivational techniques were also common, particularly in combination with personalized normative feedback. The use of drinking diaries and action plans or alcohol use “prescriptions” was also common, particularly in trials of general and older adults. A few interventions also incorporated more extensive cognitive behavioral counseling^170,^ ^175,^ ^194,^ ^196^ in conjunction with personalized normative feedback. Most trials in adolescents and young adults involved one or two in-person or Web-based personalized normative feedback sessions in school or university settings. Interventions targeting adults other than college students (including pregnant and postpartum women) were more likely to have taken place in primary care settings, had multiple sessions, and involved the primary care team in some way; approximately one-third of the interventions were delivered by the primary care clinician in trials of general and older adult populations. Three trials (with four intervention arms) involved group-based interventions,^188,^ ^194,^ ^196^ and four used a stepped-care approach,^149,^ ^208,^ ^230^ where participants who did not reduce alcohol use after a brief intervention were graduated to more intensive interventions. Six trials (in seven intervention arms) incorporated feedback on how an individual’s alcohol consumption was affecting his/her health, such as elevated liver enzymes, symptoms or medical conditions that could be exacerbated by alcohol use, and potentially dangerous alcohol use with prescribed medications.^174,^ ^176,^ ^183,^ ^188,^ ^209,^ ^222^

Table 10 Summary Intervention Characteristics for Key Questions 4 and 5 (All Intervention Conditions): Number (%) of Intervention Arms With Designated Characteristics

Population | k | Single session^*^ | | | | | Multiple sessions^*^ | | Other | Est. total contact minutes, median (range) | Web- or computer-based only | PNF | MI or ME | CBT | Other elements (no. arms) | Primary care team involved | PCP delivered most/all of intervention
Population | k | VB | | B | | E | B | E | Other | Est. total contact minutes, median (range) | Web- or computer-based only | PNF | MI or ME | CBT | Other elements (no. arms) | Primary care team involved | PCP delivered most/all of intervention
All populations | 94 | 51 (54) | | | | | 40 (43) | | 3 (3) | 30 (1-600) | 30 (32) | 58 (62) | 36 (38) | 12 (13) | | 29 (31) | 16 (17)
All populations | 94 | 18 | 15 | | 15 | | 23 | 16 | 3 (3) | 30 (1-600) | 30 (32) | 58 (62) | 36 (38) | 12 (13) | | 29 (31) | 16 (17)
Adolescents | 2 | 1 (50) | | | | | 1 (50) | | -- | 20 ^†^ | 0 (0) | 2 (100) | 1 (50) | 0 (0) | -- | 0 (0) | 0 (0)
Adolescents | 2 | 0 | | 0 | | 1 | 1 | 0 | -- | 20 ^†^ | 0 (0) | 2 (100) | 1 (50) | 0 (0) | -- | 0 (0) | 0 (0)
Adults (nonpregnant/postpartum) | 80 | 44 (55) | | | | | 33 (41) | | 3 (4) | 30 (1-600) | 27 (34) | 53 (66) | 29 (36) | 9 (11) | -- | 29 (36) | 16 (20)
Adults (nonpregnant/postpartum) | 80 | 19 | 16 | | 9 | | 18 | 15 | | 30 (1-600) | 27 (34) | 53 (66) | 29 (36) | 9 (11) | -- | 29 (36) | 16 (20)
Young adults | 38 | 30 (79) | | | | | 7 (18) | | 1 (mail only) | 35 (1-600) | 23 (61) | 34 (89) | 10 (26) | 3 (8) | Parent involvement (2) | 2 (5) | 2 (5)
Young adults | 38 | 10 | | 12 | | 8 | 5 | 2 | 1 (mail only) | 35 (1-600) | 23 (61) | 34 (89) | 10 (26) | 3 (8) | Parent involvement (2) | 2 (5) | 2 (5)
Adults | 38 | 14 (37) | | | | | 22 (58) | | 2 (not prescribed) | 30 (3-555) | 4 (11) | 18 (47) | 17 (45) | 5 (13) | PHF (4), FRAMES (2), Stepped care (2) | 24 (63) | 13 (34)
Adults | 38 | 9 | | 4 | | 1 | 11 | 11 | 2 (not prescribed) | 30 (3-555) | 4 (11) | 18 (47) | 17 (45) | 5 (13) | PHF (4), FRAMES (2), Stepped care (2) | 24 (63) | 13 (34)
Older adults | 4 | 0 (0) | | | | | 4 (100) | | -- | 80 (30-140) | 0 (0) | 1 (25) | 2 (50) | 1 (25) | PHF (2), Stepped care (1) | 3 (75) | 1 (25)
Older adults | 4 | 0 | | 0 | | 0 | 2 | 2 | -- | 80 (30-140) | 0 (0) | 1 (25) | 2 (50) | 1 (25) | PHF (2), Stepped care (1) | 3 (75) | 1 (25)
Pregnant/postpartum | 12 | 6 (50) | | | | | 6 (50) | | | 22 (10-80) | 3 (25) | 3 (25) | 6 (50) | 3 (25) | | 0 (0) | 0 (0)
Pregnant/postpartum | 12 | 0 | 1 | | 5 | | 4 | 2 | | 22 (10-80) | 3 (25) | 3 (25) | 6 (50) | 3 (25) | | 0 (0) | 0 (0)
Pregnant women | 10 | 5 (50) | | | | | 5 (50) | | -- | 22 (10-80) | 2 (20) | 2 (20) | 4 (40) | 2 (20) | PHF (1), FRAMES (1), Partner involvement (1) | 0 (0) | 0 (0)
Pregnant women | 10 | 0 | | 1 | | 4 | 3 | 2 | -- | 22 (10-80) | 2 (20) | 2 (20) | 4 (40) | 2 (20) | PHF (1), FRAMES (1), Partner involvement (1) | 0 (0) | 0 (0)
Postpartum women | 2 | 1 (50) | | | | | 1 (50) | | -- | 30 (20-40) | 1 (50) | 1 (50) | 2 (100) | 1 (50) | FRAMES (1) | 0 (0) | 0 (0)
Postpartum women | 2 | 0 | | 0 | | 1 | 1 | 0 | -- | 30 (20-40) | 1 (50) | 1 (50) | 2 (100) | 1 (50) | FRAMES (1) | 0 (0) | 0 (0)

* Intensity categories defined as: Very brief (VB) = single contact, ≤5 min; Brief (B) = ≤15 min; Extended (E) = ≥15 min.

† Able to estimate total minutes for only one trial in adolescents.

Abbreviations: B = brief; CBT = cognitive behavioral therapy; E = extended; Est. = estimated; FRAMES = Feedback of personal risks or impairment, Responsibility, Advice, Menu, Empathy, Self-efficacy; k = number of study arms; ME = motivational enhancement; MI = motivational interviewing; No. = number; PCP = primary care provider; PHF = personalized health-related feedback; PNF = personalized normative feedback; VB = very brief.

### Summary of Results

#### Alcohol Use and Other Risky Behaviors (KQ4a)

The most commonly reported alcohol use outcome was number of drinks per week, which was reported in 45 of the included trials. On average, intervention groups reduced their drinking by 1.6 drinks per week more than control groups after 6 to 12 months, among 32 trials (in 37 analysis groups) that could be included in the meta-analysis (WMD between groups in change from baseline, −1.59 [95% CI, −2.15 to −1.03]; k=37; n=15,974; I^2^=63%) (Figure 14, Table 11). This included only one trial in adolescents, with separate entries for moderate- and high-risk users, so is primarily reflective of adult unhealthy alcohol users. Baseline use levels were highly variable, with trial baseline means ranging from 3.8 to 59.3 drinks per week across all populations, and larger effects were typically seen with larger baseline use levels. The mean drinking rate in the intervention groups changed from 20.5 drinks per week at baseline to 15.6 drinks per week at followup. In the control groups, the mean drinking rate was 20.1 drinks at baseline and 17.4 drinks at followup. Excluding trials in adolescents and young adults, whose drinking pattern was generally typified by heavy use episodes rather than daily heavy drinking, the mean number of drinks per week in adult populations changed from 26.0 drinks at baseline to 19.1 drinks at followup in the intervention groups and 25.6 drinks at baseline to 21.6 drinks in the control groups. Based on mean baseline drinking levels and mean change in drinks per week, there was a median reduction of 24 percent from baseline drinking levels after 6 to 12 months (interquartile range, 13% to 32%) in intervention participants, compared with a 16 percent reduction in the control group (interquartile range, 3% to 21%). Within-study variability in change was very large, with some participants showing large changes and others none, or even increasing their alcohol use, based on study-reported standard deviations.

Figure 14 Forest Plot of Drinks per Week (KQ4a), Mean Difference in Change Between Alcohol Counseling Intervention Groups and Control Groups, by Population

Abbreviations: CI = confidence interval; Diff. = difference; SD = standard deviation; IG = intervention group; CG=control group.

Note: Timepoint is measured in months.

This figure is a forest plot of drinks per week (KQ4a), mean difference in change between alcohol counseling interventions and control groups, by population.

Table 11 Summary of Meta-Analysis Results, Primary Drinking Outcomes for Key Question 4

Outcome (effect measure) | Population | Pooled effect (95% CI) | No. studies (groups) | N analyzed | I^2^, % | Tau^2^
Drinks per week, between-group difference in change from baseline (weighted mean difference) | All Populations | −1.59 (−2.15 to −1.03) | 32 (37) | 15,974 | 63 | 1.40
Drinks per week, between-group difference in change from baseline (weighted mean difference) | Adolescents | −1.83 (−6.45 to 2.78) | 1 (2) | 477 | 87 | 9.77
Drinks per week, between-group difference in change from baseline (weighted mean difference) | Young Adults | −0.86 (−1.29 to −0.43) | 14 (14) | 6935 | 11 | 0.07
Drinks per week, between-group difference in change from baseline (weighted mean difference) | General Adults | −2.51 (−3.81 to −1.21) | 15 (18) | 7662 | 70 | 3.73
Drinks per week, between-group difference in change from baseline (weighted mean difference) | Older Adults | −2.98 (−6.96 to 0.99) | 2 (2) | 665 | 81 | 6.77
Drinks per week, between-group difference in change from baseline (weighted mean difference) | Pregnant Women | NR | 0 | -- | -- | --
Drinks per week, between-group difference in change from baseline (weighted mean difference) | Postpartum Women | −2.28 (−3.59 to −0.96) | 1 (1) | 235 | NA | NA
% Exceeding recommended drinking limits (OR) | All Populations | 0.60 (0.53 to 0.67) | 15 (16) | 9760 | 24 | 0.01
% Exceeding recommended drinking limits (OR) | Adolescents | NR | 0 | -- | -- | --
% Exceeding recommended drinking limits (OR) | Young Adults | 0.71 (0.60 to 0.86) | 2 (2) | 3068 | 0 | 0.0
% Exceeding recommended drinking limits (OR) | General Adults | 0.56 (0.49 to 0.65) | 10 (11) | 4964 | 14 | 0.01
% Exceeding recommended drinking limits (OR) | Older Adults | 0.58 (0.41 to 0.80) | 3 (3) | 1728 | 24 | 0.02
% Exceeding recommended drinking limits (OR) | Pregnant Women | NR | 0 | -- | -- | --
% Exceeding recommended drinking limits (OR) | Postpartum Women | NR | 0 | -- | -- | --
% With heavy use episodes (OR) | All Populations | 0.67 (0.58 to 0.77) | 12 (14) | 8108 | 24 | 0.01
% With heavy use episodes (OR) | Adolescents | 0.55 (0.22 to 1.34) | 1 (2) | 477 | 52 | 0.24
% With heavy use episodes (OR) | Young Adults | 0.81 (0.63 to 1.05) | 2 (2) | 2247 | 0 | 0.0
% With heavy use episodes (OR) | General Adults | 0.65 (0.53 to 0.81) | 6 (7) | 3683 | 44 | 0.03
% With heavy use episodes (OR) | Older Adults | 0.59 (0.44 to 0.80) | 3 | 1701 | 0 | 0.0
% With heavy use episodes (OR) | Pregnant Women | NR | 0 | -- | -- | --
% With heavy use episodes (OR) | Postpartum Women | NR | 0 | -- | -- | --
% Abstinent from alcohol (OR) | Pregnant Women | 2.26 (1.43 to 3.56) | 5 | 796 | 0 | 0.0

Abbreviations: CI = confidence interval; N = number of participants; No. = number; NR = not reported; OR = odds ratio.

A small-study effect was identified for drinks per week (Egger’s test bias coefficient, −1.04; p=0.031) (Figure 19), meaning that publication bias is a risk in this body of evidence, and is discussed more below, under “Heterogeneity in Effect Size.” Trials that could not be included in the meta-analysis generally showed effects of a similar size or slightly smaller, favoring the intervention group (e.g., between-group differences in change ranging from 0.9 to 1.8, or posttest differences of 2.3 drinks/week, or 10% to 20% relative reductions in use). The effects remained statistically significant when limited to trials conducted in primary care settings (WMD, −2.38 [95% CI, −3.44 to −1.33]; k=21; I^2^=70%), in the United States (WMD, −1.27 [95% CI, −1.91 to −0.62]; k=18; I^2^=64%), and in U.S.-based primary care settings (WMD, −1.75 [95% CI, −2.88 to −0.61; k=9; I^2^=77%) (Figure 15). Results remained statistically significant when the more conservative restricted maximum likelihood model was used for pooling (data not shown). Among trials conducted in primary care settings, pooled effects were very similar between interventions that did and did not involve the primary care team (Figure 15).

Figure 15 Forest Plot of Subgroup and Sensitivity Analysis Results for Drinks per Week (KQ4a), Mean Difference in Change Between Alcohol Counseling Intervention Groups and Control Groups, by the Indicated Subgroup of Trials

Abbreviations: CI = confidence interval; Diff. = difference; k = number analyzed (trials or trial arms); PC = primary care; YA = young adult.

This figure is a forest plot of subgroup and sensitivity analysis results for drinks per week (KQ4a), mean difference in change between alcohol counseling interventions and control groups, by the indicated subgroup of trials.

Figure 19 Funnel Plot of Between-Group Difference in Change From Baseline in Drinks per Week, by Standard Error (KQ4a)

Abbreviations: KQ = key question; SE = standard error.

This figure is a funnel plot of between-group difference in change from baseline in drinks per week by its standard error (KQ4a).

For trials with multiple followup assessments, effects were typically maintained between 6 and 12 months of followup; however, in several trials of young adults, the statistical significance disappeared between 6 and 12 months. Across all populations, four trials found that treatment benefits were maintained through 24^157,^ ^198,^ ^201^ to 48^153^ months, but the effect disappeared between 12 and 48 months in another.^165^ Two other trials reported no group differences at 24^233^ and 36^206^ months of followup, but interim assessments were either not conducted or had unacceptably high attrition and were not abstracted, so it is unknown whether these interventions were effective in the short term.

We also found a pooled 40 percent reduction in the odds of participants exceeding recommended drinking limits at followup (OR, 0.60 [95% CI, 0.53 to 0.67]; k=16; n=9,760; I^2^=24%) (Figure 16, Table 11), although this outcome was reported in only 24 percent (16/68) of the included studies. Between 15 and 76 percent of participants exceeded recommended drinking limits at followup in the intervention groups, compared with 29 to 82 percent in the control groups. Similarly, there was a 33 percent reduction in the pooled odds of reporting an episode of heavy use (OR, 0.67 [95% CI, 0.58 to 0.77]; k=14; n=8,108; I^2^=24%) (Figure 17, Table 11), which was also relatively sparsely reported. Small-study effects were not detected for either of these outcomes. The nine trials in pregnant women were most likely to report the odds of abstinence, rather than the aforementioned outcomes, which was doubled in the intervention groups, compared with control groups (pooled OR, 2.26 [95% CI, 1.43 to 3.56]; k=5; n=796; I^2^=0%) (Figure 18, Table 11). Other alcohol use outcomes were very sparsely reported and generally showed very small statistically nonsignificant group differences.

Figure 16 Forest Plot of Odds Ratios for Exceeding Recommended Limits (KQ4a), Comparing Alcohol Counseling Intervention Groups and Control Groups, by Population

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; KQ = key question; n = number of participants analyzed; OR = odds ratio.

Note: Timepoint is measured in months.

This figure is a forest plot of odds ratios for exceeding recommended limits (KQ4a), comparing alcohol counseling interventions and control groups, by population.

Figure 17 Forest Plot of Odds Ratios for Reporting a Heavy Use Episode (KQ4a), Comparing Alcohol Counseling Intervention Groups and Control Groups, by Population

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; n = number of participants analyzed; OR = odds ratio.

Note: Timepoint measured in months.

This figure is a forest plot of odds ratios for reporting a heavy use episode (KQ4a), comparing alcohol counseling interventions and control groups, by population.

Figure 18 Forest Plot of Odds Ratios for Reporting Abstinence During Pregnancy (KQ4a), Comparing Alcohol Counseling Intervention Groups and Control Groups, Among Trials in Pregnant Women

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; KQ = key question; OR = odds ratio; w = weeks; n = number of participants randomized.

This figure is a forest plot of odds ratios for reporting abstinence during pregnancy (KQ4a), comparing alcohol counseling interventions and control groups, among trials in pregnant women.

Few changes in other behavioral outcomes were noted, such as in drug use, sex after alcohol use, and seeking help for unhealthy alcohol use, and were only rarely reported. One trial^152^ in a general adult population found a reduction in self-reported drinking and driving, but two in younger^170^ and older^183^ adults did not. The trial in older adults reported that participants reduced the likelihood of using alcohol in the face of symptoms or comorbidities that could be exacerbated by alcohol, and with medication that could interact negatively with alcohol.^183^

Among trials reporting drinks per week, several reported effects separately for males and females^153,^ ^168,^ ^171,^ ^174,^ ^175,^ ^193,^ ^206,^ ^234^ or were entirely limited to males^192,^ ^208,^ ^220^ or females.^158,^ ^196,^ ^218^ Meta-analyses limited to men only and women only showed very similar between-group effects (WMD, −2.79 [95% CI, −4.10 to −1.49]; k=11; I^2^=45 and −2.81 [95% CI, −4.45 to −1.17]; k=9; I^2^=56 for men and women, respectively, data not shown). Among these trials, however, one found a substantially larger effect for men^206^ and two others showed smaller statistically nonsignificant differences favoring men,^171,^ ^174^ but none of these trials reported the statistical significance of treatment-by-sex interactions. Four other trials reported testing the interaction between treatment effect and sex for an alcohol use outcome, with mixed results; three trials found larger relative treatment effects in women,^149,^ ^165,^ ^197^ and one reported no interaction effect.^205^ Further, results of trials with interventions tailored to women were very limited, aside from those that targeted pregnant and postpartum women, and, with one exception,^201^ did not demonstrate superior effects.^190,^ ^196,^ ^218,^ ^227^

Across a variety of alcohol use outcomes, a few studies explored differential effects by subgroups other than sex, including baseline drinking severity,^149,^ ^170,^ ^193,^ ^199,^ ^202,^ ^210^ readiness to change,^170,^ ^193,^ ^205^ drinking pattern,^165^ race/ethnicity,^191,^ ^203^ socioeconomic characteristics,^206^ and the presence of mental health comorbidities.^149^ Several trials found larger effects in patients with heavier baseline use on at least one outcome^149,^ ^193,^ ^199,^ ^210^ or trends in that direction,^170^ although most did not report interaction tests. Few trials found differences in other subgroups, and none of the differences that were found were replicated. Since subgroup effects were reported only rarely, there is a risk that statistically significant results were preferentially published, so reported results may exaggerate subgroup differences in intervention benefit.

#### Heterogeneity in Effect Size

The effect size for our primary outcome, drinks per week, was larger in the subset of trials that had been included in the previous review (WMD, −2.83 [95% CI, −3.89 to −1.76]; k=15; I^2^=68%) than those that were newly included (WMD, −0.77 [95% CI, −1.24 to −0.30]; k=22; I^2^=28). Exploratory analyses indicated that several factors were associated with effect size and likely explained the difference between the effects in studies in the current and previous reviews, including population (young adults vs. adults of other ages), setting (primary care vs. other), study sample size, baseline alcohol use, and year of publication. However, these factors were not independent of each other, and we were unable to determine which of these had a causal association with effect size.

Across all studies included in the meta-analysis for drinks per week (30 trials in adults of varying ages, including one in postpartum women and one in adolescents), a statistically significant small-study bias was detected (p=0.031) (Figure 19). Smaller trials were more likely to have been published more than 10 years ago and to have been among heavier drinkers. The median sample size in studies published in 2007 or later was roughly twice as large (median n analyzed, 360 [range, 90 to 1488]) as those published before 2007 (median n analyzed, 158 [range, 61 to 774]). Similarly, baseline drinks per week in trials published since 2007 (median, 10 [range, 4 to 54]) were less than half of those in older trials (median, 22 [range, 11 to 64]). Figure 20 provides a visual display of the association between effect size and baseline alcohol use, showing the distribution of studies by baseline drinks per week in the control group by publication year. The size of the marker is weighted by the mean difference between groups in change from baseline, so trials with larger between-group differences have larger markers. The scatter plot shows that larger effects generally appear on the upper half of the figure (higher baseline drinks per week) and on the left (earlier publication year).

Figure 20 Scatter Plot of Baseline Alcohol Use in the Control Groups by Year of Publication, With Marker Weighted by the Between-Group Absolute Difference in Change From Baseline*

* Mean difference was set to 0.1 if the control group reported a greater reduction in alcohol use than the intervention group.

This figure is a scatter plot of baseline alcohol use in the control groups by year of publication, with marker weight by the between-group absolute difference in change from baseline.

Older trials were also primarily conducted in general adult populations in primary care settings, while many of the newer trials were conducted in young adults in college settings, with baseline use levels that were considerably lower than in trials targeting general adult populations. Followup analyses found that the pooled effects were smaller, but still statistically significant, when limited to trials published in 2007 or later, with an average reduction of 1.1 drinks per week (Figure 15) and a 35 percent reduction in the odds of exceeding recommended drinking limits (OR, 0.65 [95% CI, 0.56 to 0.76]; k=8; n=6,569; I^2^=23%; data not shown). This effect is not entirely due to the greater proportion of trials in young adults in the recent literature; when comparing effects between older and newer studies and excluding the trials in young adults, effects were still larger in the older literature, but differences were less pronounced (e.g., −1.59 drinks per week in more recent literature vs. −3.6 drinks per week in older literature) (Figure 15).

We did not find any treatment elements that were clearly associated with effect size (e.g., multisession vs. single-session contact, direct personal contact vs. computer or mail-only contact, estimated contact minutes, use of personalized normative feedback [vs. not], use of motivational techniques [vs. not], whether the primary care provider delivered the counseling [vs. not] among trials conducted in primary care). The lack of association with treatment elements held up even within baseline alcohol use strata (≤14 drinks/week, >14 to 28 drinks/week, >28 drinks/week). However, among the trials of general and older adults there was a near statistically significant effect, showing larger effects with multiple- versus single-contact interventions (p=0.07), but this was not the case for trials limited to young adults (p=0.61). Effect size was not influenced by study quality (fair vs. good), loss to followup, whether the trials targeted economically disadvantaged persons, or whether the trial included more than 50 percent racial/ethnic minority persons.

#### Health, Social, and Legal Outcomes (KQ4b)

The most commonly reported health outcome was alcohol-related problems or consequences, measured using a variety of instruments. A pooled analysis showed a statistically significant, but very small, standardized mean difference in change between groups of −0.04 (95% CI, −0.09 to −0.01; k=18; I^2^=3%). This effect size (Hedge’s g) can be interpreted as a Cohen’s d, where a small effect is typically considered to be 0.20 to 0.50.^250^ Mortality was reported in eight trials, primarily as part of the description of the participant retention. The pooled effect was not statistically significant (OR, 0.64 [95% CI, 0.34 to 1.19]; k=9; n=4,533; I^2^=0%) (Figure 21), and also likely represents an overestimate of the true effect, since many trials that did not report deaths likely had no deaths, particularly those in young adults. Trials were not powered for this outcome and many had very few events, resulting in imprecise results. Only one trial, the Trial for Early Alcohol Treatment (TrEAT), described ascertainment methods.^153^ This trial conducted a careful assessment of health outcomes through 4 years, based on self-report as well as electronic medical records, and databases from the government Crime Information Bureau, Department of Transportation, and Vital Statistics records. This trial found a statistically nonsignificant reduction in mortality at 4 years, with 0.8 percent (3/392) of intervention participants dying compared with 1.8 percent (7/382) of control participants. The difference in mortality between groups was statistically significant at 3 years of followup, when there had been only one death among intervention participants but seven among control participants. The trial did not report whether any of these were related to alcohol use; however, two deaths in the control group were due to car accidents. Other causes of death were coronary artery disease and respiratory failure (in the control group), and suicide and myocardial infarction (in the intervention group).

Figure 21 Forest Plot of Odds Ratios for Mortality (KQ4b), Comparing Alcohol Counseling Intervention and Control Groups, by Population

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; KQ = key question; n = number of participants analyzed; OR = odds ratio.

Note: Timepoint is measured in months.

This figure is a forest plot of odds ratios for mortality (KQ4b), comparing alcohol counseling interventions and control groups, by population.

The TrEAT trial also reported statistically significant reductions in days of hospitalization (420 in the intervention vs. 664 in the control group) and controlled substance or liquor violations (two in the intervention vs. 11 in the control group) at 4 years of followup. In addition, it reported statistically nonsignificantly fewer emergency department visits (302 in intervention vs. 376 in the control group) and motor vehicle crashes with nonfatal injuries (20 in intervention vs. 31 in the control group) after 4 years. Other trials reported a wide variety of health outcomes, generally at 6 to 12 months of followup, with few findings of benefit for intervention over control groups.

#### Harms (KQ5)

Few studies reported on harms, and none identified any increased risk of harms with the included interventions. Further, no pattern of unexpected paradoxical increases in alcohol use was noted with these interventions.

### Detailed Results, by Subpopulation

#### Adolescents

##### Study, Population, and Intervention Characteristics

Two trials targeted adolescents (n=1,160), one fair-quality^215^ and one good-quality,^210^ both published since the previous review. Both trials only reported results by subgroup, one by sex^215^ and the other by baseline severity.^210^ Retention was high in both trials, with 98 percent^215^ and 93 percent^210^ retention at 6 months of followup.

The first trial (n=119) involved a 20-minute counseling session for 14- to 18-year-olds attending primary care visits at either a large, urban, academic medical center or a public health clinic in the southeastern United States.^215^ This intervention used a motivational enhancement approach that also included personalized normative feedback and discussion of alcohol use in their peer network. Youth in this study were age 16.4 years on average; 71 percent were female and 84 percent were black. Youth were eligible if they scored 2 or 3 on the CRAFFT with respect to alcohol or marijuana use, indicating they were at risk for a substance use disorder.

The other trial (n=469, among relevant subgroup) involved a single Web-based personalized normative feedback session among Swiss high school students (ages 16 to 19 years) followed by text messages tailored to the students’ baseline risk level.^210^ Average age in this trial was 16.8 years, 53 percent were female, and race/ethnicity was not reported. The trial included all students, regardless of alcohol use level, but reported results separately for those with and without unhealthy use. We limited our inclusion to the subgroup with unhealthy alcohol use, which was defined as one or more episodes of heavy use in the previous 30 days or more than 14 (males) or seven (females) drinks consumed in a typical week. This group was further divided into two subgroups, with results only reported separately: those with more than two heavy use episodes in the previous 30 days (“high risk”) and those with one or two heavy use episodes (“moderate risk”).

##### Alcohol Use and Other Risky Behaviors (KQ4a)

Both trials found beneficial effects in one of two subgroups reported, and neither reported overall effects for the subgroups combined.

The U.S.-based study targeting alcohol and drug use found a statistically significant treatment-by-sex interaction and only reported results by sex, with beneficial effects seen only for males. Alcohol use during the previous 30 days decreased among males in the intervention group (from 0.52 to 0.25 on a scale of 0–7) and increased among males in the control group (0.50 to 0.81) over 6 months (Cohen’s d=0.50; p<0.05). For females, alcohol use was slightly higher at baseline in the intervention group (1.19 vs. 0.69 in the control group), but both groups averaged around 0.8 at 6 months of followup (Cohen’s d not reported; p>0.05). The scale used for this study was: 0=0 days, 1=1–2 days, 2=was not reported, 3=3–5 days, 4=6–9 days, 5=10–19 days, 6=20–29 days, and 7=all 30 days.

The Swiss study of high school students found beneficial results only for the high-risk students; that is, those reporting more than two episodes of heavy use in the previous month. Among these students, the number of drinks per week and heavy use episodes in the previous 30 days had declined by 7.95 drinks and 1.48 episodes at 6 months of followup, respectively, in the intervention group, compared with reductions in the control group of 3.54 drinks and 0.86 episodes. The reduction in heavy use episodes was statistically significant; drinks per week was not statistically significant in the adjusted model, although the unadjusted result shown in the forest plot was statistically significant (Figure 14). Reductions were smaller and between-group differences were not statistically significant for the moderate-risk group; in the intervention and control groups, drinks per week declined by 0.94 and 1.26, respectively, and heavy use episodes declined by 0.05 and 0.06.

##### Health, Social, and Legal Outcomes (KQ4b)

Neither study reported on health, social, or legal outcomes.

##### Harms (KQ5)

Neither study reported on harms related to the intervention.

#### Young Adults

##### Study, Population, and Intervention Characteristics

We identified 22 trials that targeted young adults (n=14,214). Most (20/22) of the trials in younger adults were conducted in university settings, including the four primary care–based trials,^160–162,^ ^170^ which were conducted in university health clinics. Two-thirds (15/22) were conducted in the United States, and the remaining were in Europe, Canada, Australia, and New Zealand. Four trials were rated as good quality,^161,^ ^205,^ ^220,^ ^226^ and median retention across all trials was 84 percent (range, 65% to 90%) at 6 to 12 months of followup. The average participant age was 19.8 years, 51.5 percent of participants were female, and most participants were white or Asian. Most trials of young adults selected participants based on the presence of heavy use episodes, typically defined as four or more drinks on one occasion for females and five or more drinks on one occasion for males. Almost 90 percent (34/36) of the interventions in these trials involved personalized normative feedback, usually delivered in one or two brief sessions, with more than half delivered via computer or the Web and no or minimal direct interaction with study staff. One study (with two treatment arms) involved parents via mailed materials.^205^ Four of these trials were included in the previous review.^160,^ ^161,^ ^170,^ ^178^

##### Alcohol Use and Other Risky Behaviors (KQ4a)

Young adults reduced their alcohol use by an average of 0.87 drinks per week (WMD, −0.86 [95% CI, −1.29 to −0.43]; k=14; n=6,935; I^2^=11%) (Figure 14). Results were similar when we dropped the trials that had no alcohol use restrictions, and therefore included some participants who were not unhealthy alcohol users (WMD, −0.89 [95% CI, −1.52 to −0.26]; k=12; n=4,864; I^2^=24%). The five trials that could not be included in the meta-analysis showed similarly modest effects,^161,^ ^162,^ ^195,^ ^196,^ ^201^ with between-group differences in change ranging from −0.9 to −1.8, and three trials reporting 10 and 20 percent reductions in risk-negative binomial models. Interestingly, one additional primary care–based trial targeting a general adult population, published in 1997, reported subgroup analyses for younger adults (ages 18 to 30 years), and found substantially larger effects; intervention participants reported a reduction of 4.1 drinks per week (95% CI, −7.1 to −1.1) more than control group participants at 12 months of followup.^153^ Baseline use in the young adult subgroup of this study was 18 drinks per week, which is an average of seven more drinks per week than in trials limited to young adults.

Of the six trials reporting results at both 6 and 12 months, four found that benefits at 6 months were no longer statistically significant at 12 months for at least one intervention group.^162,^ ^170,^ ^189,^ ^223^ Only two trials reported outcomes beyond 12 months,^198,^ ^201^ and both found that benefits were maintained through 24 months, although only for the most intensive and specifically tailored intervention group in one of these trials.^201^ A number of trials included multiple intervention groups,^162,^ ^189,^ ^199,^ ^201,^ ^205,^ ^211,^ ^223,^ ^225^ and we used the group we judged to be most intensive or comprehensive; other intervention groups showed comparable or smaller effects on drinks per week and other alcohol use outcomes. One trial in a general adult population found that 12-month benefits for drinks per week were maintained through 24 months in a subgroup analysis of younger adults ages 18 to 30 years, but were smaller and no longer statistically significant at 36 months of followup.^153^

Most trials in young adults recruited participants with episodes of heavy use; however, this outcome did not show a benefit of treatment in this population, either as number of heavy use episodes per week (WMD, −0.06 [95% CI, −0.16 to 0.05]; k=7; n=2,968; I^2^=33%; data not shown) or as the proportion with heavy use episodes in the previous month (OR, 0.81 in each of two trials; neither statistically significant) (Figure 17). However, the trial targeting a general adult population that reported subgroup analyses for younger adults did find larger effects for heavy use episodes, as well as for drinks per week; intervention participants reported a reduction of 2.0 more heavy use episodes per month (95% CI, −3.1 to −0.9) than control group participants after 1 year.^153^ Among trials limited to young adults, both trials that reported the proportion exceeding recommended limits showed improvements over control; reductions in the odds of exceeding limits were 35 percent (95% CI, 46% to 92%)^195^ and 26 percent (95% CI, 60% to 91%).^197^ Pooled effects were not statistically significant for drinks per drinking day (WMD, −0.40 [95% CI, −0.90 to 0.10]; k=4; n=1,026; I^2^=56%; data not shown).

Four trials in young adults were conducted in primary care settings,^160–162,^ ^170^ and three of these had positive results across multiple drinking outcomes after 6 months, but group differences were not maintained at 12 months.^160,^ ^162,^ ^170^ The fourth trial showed statistically nonsignificant 10 to 20 percent reductions in risk across three alcohol use outcomes, assessed only at 6 months of followup.^161^

One trial each reported no between-group differences in self-reported drinking and driving^170^ or in marijuana-related consequences.^201^

##### Health, Social, and Legal Outcomes (KQ4b)

Thirteen trials reported results for alcohol-related problems or consequences, and the pooled estimate showed a small but statistically significant standardized difference in favor of the intervention groups (standardized mean difference [Hedge’s g], −0.06 [95% CI, −0.11 to −0.01]; I^2^=0%) (Figure 22). This is a very small effect, with even the upper CI falling well below what would usually be considered a small effect size. The most commonly used instrument was the Rutgers Alcohol Problems Index (RAPI), a 23-item instrument asking how many times respondents had experienced the list of problems due to alcohol use, such as not being able to do homework or study for a test, getting into fights, neglecting responsibilities, and finding yourself in a place you could not remember getting to. It also includes some items specifically about alcohol use (“feel that you had a problem with alcohol,” “want to stop drinking but can’t”). Included trials used different versions, with response category values of 0–1, 0–3, and 0–4. Three trials also reported scales measuring academic effects, with one reporting greater improvements in the intervention groups (negative binomial rate ratio [RR], 0.8; p<0.05 at 6 and 12 months of followup);^162^ the other two did not find statistically significant group differences (negative binomial RR, 0.9; p=0.87^195^ and median Academic Role Expectations and Alcohol Scale score, 4 [out of 35] in the control group vs. 2 in the intervention group; p=0.06,^161^ both at 6 months of followup). Two other trials found no between-group differences in risk-taking behavior^170^ or a composite health care utilization outcome that included inpatient, emergency department, urgent care, and detox services.^160^

Figure 22 Forest Plot of Standardized Mean Difference in Change Between Groups on Measures of Alcohol-Related Problems or Consequences (KQ4b)

Abbreviations: APQ = Alcohol Problems Questionnaire; BYAACQ = Brief Young Adult Alcohol Consequences Questionnaire; CI = confidence interval; SD = standard deviation; IG = intervention group; CG = control group; Diff. = difference; DPI = Drinking Problems Index; RAPI = Rutgers Alcohol Problem Index; SD = standard deviation; SIP = Short Inventory of Problems; YAAPST = Young Adult Alcohol Problems Screening Test.

Note: Timepoint is measured in months.

This figure is a forest plot of standardized mean difference in change between groups on measures of alcohol-related problems or consequences (KQ4b).

##### Harms (KQ5)

Three trials reported no adverse effects in both groups.^197,^ ^201,^ ^225^ Two trials had point estimates that favored the control group by less than one drink per week; however, these effects appeared consistent with true, underlying effect being scattered around a small beneficial effect on average, and individual study results falling a small distance on either side of the average effect.^189,^ ^223^ Thus, no pattern of paradoxical effects was identified that would indicate that these interventions could be harmful in young adults.

#### General Adult Populations

##### Study, Population, and Intervention Characteristics

We identified 29 trials (n=16,944) that targeted adults of all ages. Most trials in general adult populations were conducted in primary care settings (24/29 [83%]). Ten trials altogether were conducted in the United States; the remaining studies were conducted in Canada, Australia, and Europe. Three trials were rated as good quality,^153,^ ^168,^ ^234^ and across all trials the median retention was 77 percent (range, 59% to 96%) at 6 to 24 months of followup. The average age was 44.7 years; 42 percent of participants were female. Among trials conducted in the United States, where race/ethnicity was most consistently reported, 76 percent of participants were white, 19 percent were black, and 17 percent were Hispanic; four included majority nonwhite samples.^169,^ ^188,^ ^218,^ ^246^ Five of the trials had a substantial proportion of participants who were socioeconomically disadvantaged (i.e., >50% of participants were uninsured or on Medicaid, on public assistance, unemployed, or had an annual income of <$15,000).^168,^ ^169,^ ^188,^ ^218,^ ^224^ Almost half (18/38) of the interventions in these studies included personalized normative feedback, and three trials (with four intervention arms) also included personalized feedback about health effects related to their alcohol use.^174,^ ^188,^ ^209^ Most of these interventions took place in person, and 63 percent (24/36) involved the participant’s primary care team; the primary care clinician delivered most or all of the intervention in 34 percent (13/36) of the interventions. Eleven of these trials were included in the previous review.^149,^ ^152,^ ^153,^ ^163,^ ^165,^ ^168,^ ^169,^ ^171,^ ^172,^ ^174,^ ^175^

##### Alcohol Use and Other Risky Behaviors (KQ4a)

Drinks per week totals were reduced in general adult populations by an average of three drinks per week (WMD, −2.51 [95% CI, −3.81 to −1.21]; k=18; n=7,662; I^2^=70%) (Figure 14). Five of the six trials that reported this outcome but could not be included in the meta-analysis did not show statistically significant differences,^152,^ ^172,^ ^185,^ ^188,^ ^218,^ ^228^ with effects across all six studies ranging from −1.3^152^ to −3.1^172^ greater reduction in drinks per week in the intervention group, to 2.3^185^ fewer drinks per week at followup in the intervention group. Effects were generally consistent with respect to statistical significance across multiple intervention groups or attenuated with less intensive approaches,^149,^ ^175,^ ^186,^ ^188,^ ^209,^ ^228,^ ^234^ although one trial did find larger effects at 12 months (but not 6 months) of followup with a single 10- to 15-minute advice session than with the more intensive arm that offered a 30- to 40-minute motivational enhancement intervention followed by two brief booster sessions.^163^ Two trials reported outcomes for drinks per week beyond 12 months; one found that benefits dropped off at 24 months,^165^ but the other study maintained a difference of 0.3 greater reduction in drinks per week in the intervention group than the control group through 48 months (from −0.4 drinks/week difference at 12 months of followup).^153^

The odds of exceeding recommended limits were reduced by 44 percent (OR, 0.56 [95% CI, 0.49 to 0.65]; k=11; n=4,964; I^2^=14%) (Figure 16). Heavy use episodes were reduced by 35 percent (OR, 0.65 [95% CI, 0.53 to 0.81]; k=7; n=3,683; I^2^=44%) (Figure 17). Three trials reported other behavioral outcomes: one reported lower self-reported drinking and driving (20% in the intervention group vs. 35% in the control group reported that in the previous month they had driven after more than two drinks) (OR, 0.46 [95% CI, 0.27 to 0.76]),^152^ one found no between-group differences for having sex after drinking among patients attending a sexual health clinic (OR, 0.79 [95% CI, 0.33 to 1.75]),^185^ and the third found no differences in the number of days participants had used drugs (mean difference in change, −4.5 [95% CI, -24 to 15]).^218^

A few trials in general adult populations reported effects of subgroup analyses. One trial reported no interactions with age, education, marital status, or employment status,^206^ but only examined these interactions in males. Another trial reported a treatment benefit only in persons drinking above recommended limits but without an AUD or heavy use episodes in the previous month, while no clear benefit was found in those with AUD or heavy use episodes at baseline.^149^ A third trial found no differences in treatment effect in older adults versus younger and middle-aged adults.^163^

##### Health, Social, and Legal Outcomes (KQ4b)

Five trials reported mortality outcomes, usually as part of a description of the participant flow, and none found an effect on mortality. This included the TrEAT trial, with 4 years of followup and well-reported ascertainment methods, which found that 0.8 and 1.8 percent of intervention and control participants had died, respectively.^153^ As covered in the overall summary of results above, at 4 years of followup, this trial found reductions in days hospitalized (420 in the intervention vs. 664 in the control group) and controlled substance or liquor violations (two in the intervention vs. 11 in the control group), as well as statistically nonsignificant differences in emergency department visits (302 in intervention vs. 376 in control group) and motor vehicle crashes with nonfatal injuries (20 in intervention vs. 31 in control group). Aside from the TrEAT trial, six^188,^ ^206,^ ^208,^ ^209,^ ^218,^ ^246^ other trials reported various self-rating medical or physical health items or scales, and between-group differences favoring the intervention group were found in only one study, on the Medical subscale of the Addictions Severity Index (detailed data not reported).^188^ The others reported small effects that did not consistently favor the intervention groups for these outcomes. Similarly, one trial reported quality-adjusted life-years,^219^ five reported various mental health–related scale scores, and none found group differences at 6 to 12 months of followup.^188,^ ^206,^ ^208,^ ^218,^ ^246^ Other outcomes that were reported (excluding the TrEAT trial) almost always showed no clinically or statistically important differences between groups, and included general consequences scales;^208,^ ^218,^ ^230,^ ^240^ legal,^188^ employment,^188^ and family/social scales;^171,^ ^188^ liver enzymes;^171,^ ^188,^ ^193,^ ^206^ blood pressure;^224^ hospitalizations;^172^ and accidents.^171^

##### Harms (KQ5)

One trial reported no adverse events in any arms of the trial.^149^ Although no pattern of paradoxical effects was identified that would indicate that these interventions could be harmful in general adult populations, one trial did report that control group participants were more likely than intervention participants to be below the AUDIT cutoff of 8, indicating nonproblematic levels of alcohol use.^233^ However, in this trial, the point estimates favored the intervention group for the related outcomes of exceeding recommended limits and heavy use episodes, suggesting no actual harm.

#### Older Adults

##### Study, Population, and Intervention Characteristics

Four trials focused on older adults (n=2,504), with minimum ages ranging from 55 to 65 years (average age, 68.5 years), all in primary care settings; three were conducted in the United States^157,^ ^176,^ ^183^ and one in Great Britain.^230^ Two trials were rated as good quality,^183,^ ^230^ and retention across all four trials ranged from 83 to 92 percent. Thirty percent of the participants were female, and there was minimal representation of racial/ethnic minority or low socioeconomic status patients. All of these interventions included multiple contacts, combining in-person and phone contacts. One used a stepped-care approach and had repeat visits only if participants hadn’t changed their alcohol use at a 4-week followup call.^230^ Two of these trials were included in the previous review.^157,^ ^176^

##### Alcohol Use and Other Risky Behaviors (KQ4a)

Three of the trials in older adults^157,^ ^176,^ ^183^ reported number of drinks per week at 12 months of followup, all showing greater reductions in the intervention groups (Figure 13). Differences in change between groups ranged from −2.2 (95% CI not reported; p<0.01)^183^ (not included in the meta-analysis) to −5.3 (95% CI, −8.5 to −2.1),^157^ from baseline use levels of 14 to 17 drinks per week. Beneficial effects were maintained through 24 months in one trial, at which point intervention group participants had reduced their drinking by an average of three more drinks per week than control group participants (p<0.001).^157^ The same three trials also reported reductions in the proportion exceeding recommended drinking limits after 12 months, with ORs ranging from 0.33 (95% CI, 0.15 to 0.73)^157^ to 0.75 (95% CI, 0.42 to 1.36) (Figure 16).^176^ One trial also reported a greater reduction in the number of heavy use episodes per month at 12 months (mean difference in change, −3.1 [95% CI, −5.6 to −0.6]; p<0.001), but the effect deteriorated and was not maintained at 24 months.^157^ Between-group differences in change were not seen for the AUDIT-C^230^ or the CARET.^176^ One trial reported that participants reduced the likelihood of using alcohol in the face of symptoms (OR, 0.60 [95% CI, 0.46 to 0.80]) or comorbidities (OR, 0.72 [95% CI, 0.53 to 0.96]) that could be exacerbated by alcohol, and with medication that could interact negatively with alcohol (OR, 0.66 [95% CI, 0.51 to 0.85]).^183^ This trial did not find group differences in driving within 2 hours of having three or more drinks, which was reported by 11 and 16 percent (p=0.27) at 6 months in the intervention and control groups, respectively, and 14 and 17 percent at 12 months of followup (p=0.06).

##### Health, Social, and Legal Outcomes (KQ4b)

One trial reported a reduction in emergency department visits (OR, 0.56 [95% CI, 0.33 to 0.96]) and in depressive symptoms (mean difference at posttest, 0.14 on a 5-point scale; p<0.05).^183^ Two trials found no statistically significant group differences in change on the SF-36 mental and physical component scores.^183,^ ^230^ Across both scales and two different time points for each study, between-group differences in change ranged from 0.4 (95% CI, −0.4 to 1.2), favoring the control group, to −1.2 (95% CI, −3.1 to 0.6), favoring the intervention group, with baseline scores ranging from 44 to 51 on a 100-point scale.

##### Harms (KQ5)

One trial reported no adverse events in either arm of the trial.^230^ No pattern of paradoxical effects was identified that would indicate that these interventions could be harmful in general adult populations.

#### Pregnant and Postpartum Women

##### Study, Population, and Intervention Characteristics

We identified 11 fair-quality trials (n=2,278) that evaluated the effectiveness of interventions to reduce alcohol use among pregnant^181,^ ^184,^ ^191,^ ^202,^ ^203,^ ^217,^ ^221,^ ^222,^ ^235^ and postpartum^158,^ ^212^ women. One trial was conducted in the Netherlands^222^ and the other 10 were conducted in the United States. The trials targeting pregnant women took place in outpatient obstetric settings, usually at prenatal visits during the first^184,^ ^203,^ ^222^ or second^181,^ ^191,^ ^202,^ ^217,^ ^221,^ ^235^ trimester. The trials in postpartum women recruited in the hospital postdelivery^212^ and at a 6-week postnatal visit.^158^ Median retention was 81 percent (range, 63% to 100%) after 1 to 12 months; most of the trials followed the women for 6 months or less. Among the studies in the United States, approximately half of participants were white, 31 percent were black, and 15 percent were Hispanic. Seven of these trials included a substantial number of socioeconomically disadvantaged women.^184,^ ^202,^ ^203,^ ^212,^ ^217,^ ^221,^ ^235^ The interventions in these populations involved one to four sessions, which were generally described as “brief” or 10 to 20 minutes in length, for a total contact time ranging from an estimated 10^203^ to 80^184^ minutes. Six interventions^158,^ ^184,^ ^212,^ ^217,^ ^221,^ ^235^ used motivation techniques and another used the transtheoretical model framework, suggesting use of different motivational techniques for participants in different stages of change with regard to alcohol use.^222^ Three interventions described the use of cognitive behavioral techniques.^158,^ ^202,^ ^203^ Three of the interventions were delivered via computer or the Web, with minimal contact with study staff.^212,^ ^222,^ ^235^ Two of these trials were included in the previous review.^158,^ ^181^

##### Alcohol Use and Other Risky Behaviors (KQ4a)

The most commonly reported outcome in trials targeting pregnant women was abstinence from alcohol. The pooled odds of abstaining from using alcohol during pregnancy was nearly doubled in the intervention groups, compared with control groups (OR,1.92 [95% CI, 1.19 to 3.09]; k=5; n=796; I^2^=9%) (Figure 18); however, the recall range was highly variable, ranging from 1 to 3 months. The percent of reported abstinence in the control groups ranged from 11 to 89 percent, while intervention groups ranged from 18 to 90 percent. However, the between-group difference in abstinence was statistically significant in only two of the five trials.^202,^ ^203^ Four trials^181,^ ^184,^ ^191,^ ^221^ reported number of drinks per drinking day, but none found differences, and in many cases the mean change values in the two groups were within 0.2 of each other, with some results favoring the control groups. Similarly, no statistically significant (or potentially clinically important) differences were detected on other drinking outcomes, such as drinks per week, drinking days per week, percent of days used alcohol, and AUDIT score.^191,^ ^221,^ ^235^ In postpartum women, one trial (n=235) reported greater reduction in drinks per month (dropping from 34 to 20 drinks/month in the intervention group, compared with a change from 32 to 27 drinks/month in the control group) and heavy use episodes per month (dropping from 10 to 7 in the intervention group vs. 10 to 9 in the control group).^158^ In the other trial in postpartum women (n=123), although mean scores consistently favored the intervention group, posttest scores did not differ statistically on number of drinking days in the previous 3 months (15 and 22 in the intervention group and control group, respectively), drinks per week (6.4 and 8.7), or heavy use episodes per week (0.56 and 0.75).^212^

Two trials of pregnant and postpartum women reported on subgroup effects. One trial in low-income pregnant women reported that treatment effects were larger in those who drank fewer than eight drinks per month (vs. ≥8 drinks/month), were African American, and were teenagers,^203^ although they did not report whether they tested interaction terms. Another trial reported a greater treatment effect on birth length among those with higher (vs. lower) baseline alcohol consumption, but no such effect for birth weight and drinks per drinking day.^202^

##### Health, Social, and Legal Outcomes (KQ4b)

Two trials reported birth weight, finding the average to be 224 g larger in the intervention group of one trial^235^ (p<0.03) but no between-group difference in the other trial.^181^ Trials also reported no differences in gestational age (detailed results not reported),^235^ head circumference (detailed results not reported),^235^ fetal mortality (OR, 0.29 [95% CI, 0.03 to 2.62]),^202^ or live birth weight of larger than 2,500 g and no admission to neonatal intensive care (OR, 3.30 [95% CI, 0.80 to 13.8]).^217^ One trial^221^ found no differences between groups on “basic psychological need satisfaction.” Neither of the trials in postpartum women reported health, social, or legal outcomes.

##### Harms (KQ5)

One trial in pregnant women reported no adverse events in either arm of the trial.^217^ No pattern of paradoxical effects was identified that would indicate these interventions could be harmful in pregnant or postpartum women.