# Chapter 2 Methods

## Scope and Purpose

This systematic review examined the evidence for the benefits and harms of screening for unhealthy alcohol use and interventions to reduce unhealthy alcohol use in nondependent alcohol users in primary care–relevant settings (primary care, other outpatient health care settings) or in other general populations judged to be comparable to primary care populations. It will be used by the USPSTF to update its 2013 recommendation on screening for alcohol misuse in primary care. The current review uses the terminology of “unhealthy” use rather than “misuse” in accordance with the American Society of Addiction Medicine, which defined “unhealthy” use as any use that increases the risk or likelihood of health consequences (hazardous use), or that has already led to health consequences (harmful use), including a diagnosis of AUD.

## Key Questions and Analytic Framework

In consultation with members of the USPSTF, we developed key questions (KQs) and an analytic framework (Appendix A Figure 1) to guide our review.

1. a. Does primary care screening for unhealthy alcohol use in adolescents and adults, including pregnant women, reduce alcohol use or improve other risky behaviors?
  b. Does primary care screening for unhealthy alcohol use in adolescents and adults, including pregnant women, reduce morbidity or mortality or improve other health, social, or legal outcomes?
2. What is the accuracy of commonly used instruments to screen for unhealthy alcohol use?
3. What are the harms of screening for unhealthy alcohol use in adolescents and adults, including pregnant women?
4. a. Do counseling interventions to reduce unhealthy alcohol use, with or without referral, reduce alcohol use or improve other risky behaviors in screen-detected persons?
  b. Do counseling interventions to reduce unhealthy alcohol use, with or without referral, reduce morbidity or mortality or improve other health, social, or legal outcomes in screen-detected persons?
5. What are the harms of interventions to reduce unhealthy alcohol use in screen-detected persons?

## Data Sources and Searches

We developed a search strategy designed to capture relevant literature published from 6 months prior to the search date in the previous USPSTF review to identify newly published studies of screening and counseling interventions (Appendix A).^83^ We then searched the following databases for relevant English-language literature published between January 1, 2011 (for KQs 1, 3, 4, and 5) or January 1, 1998 (for KQ2), and October 12, 2017: MEDLINE, PubMED (for publisher-supplied records only), PsycINFO, and the Cochrane Central Register of Controlled Trials. A research librarian developed and executed the search, which was peer-reviewed by a second research librarian.

In addition, we evaluated all relevant studies included in the previous reviews for inclusion in the current review, as well as selected studies from the “excluded studies” appendix. We also examined the reference lists of other previously published reviews, meta-analyses, and primary studies to identify additional potential studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts. We also searched ClinicalTrials.gov for ongoing trials. We imported the literature from these sources directly into EndNote® X7 (Thomson Reuters, New York, NY).

Since October 12, 2017, we have continued to conduct ongoing surveillance through article alerts and targeted searches of high-impact journals to identify major studies published in the interim that may affect conclusions. The last surveillance was conducted on August 1, 2018 and identified no primary research that would be included in our review. However, one recently published test accuracy study was identified that meets our inclusion criteria, but it did not change our conclusions and is therefore listed in the Discussion section only.

## Study Selection

We developed specific inclusion criteria to guide our study selection (Appendix A Table 2). For KQs addressing benefits and harms of screening (KQs 1 and 3) and treatment (KQs 4 and 5), we included randomized, controlled trials (RCTs), including cluster randomized trials, and non-RCTs that included a usual care, no intervention, minimal control, or attention control comparison group. For KQ2 we included studies of test accuracy reporting sensitivity and specificity compared with a structured or semistructured clinical interview. We excluded prospective and retrospective cohort studies, case control studies, time series studies, before-after studies with no comparison group, cross-sectional studies, case studies, case series, and editorials/commentaries.

We included studies conducted among adolescents or adults age 12 years or older. For KQs 1 to 3, study participants were required to not be selected on the basis of alcohol use or a related behavior. For KQs 4 and 5, studies had to have at least half of their enrolled sample recruited via population-based screening, operationalized as individual outreach to members of a defined population (or a random or consecutive sample) who had been identified as potentially eligible to complete a standardized brief instrument. Additionally, studies of participants with alcohol dependence or severe AUD (or >50% of the enrolled sample having alcohol dependence/severe AUD) were excluded. Other population exclusions included studies limited to treatment-seeking individuals, those with concomitant psychotic disorders, those presenting in an emergency setting, and others not generalizable to primary care (e.g., inpatients, those court-mandated to treatment, those who are incarcerated).

We required that studies screen for alcohol use using a brief standardized instrument or set of questions. For KQ2, we limited the evidence to the most widely used screening instruments and those most feasible for application in primary care. This included those identified in the previous review as having the best evidence to support their use (AUDIT, AUDIT-C, SASQ) and those named in national-level recommendations related to screening for unhealthy alcohol use (AUDIT-C, SASQ). We also included variations of the AUDIT and AUDIT-C, such as the USAUDIT/USAUDIT-C and those translated to other languages. Additionally, we selected instruments that target important subpopulations (adolescents [NIAAA two-item screener, BSTAD], pregnant women [TWEAK, T-ACE], or older adults [CARET]), or that cover both drug and alcohol use (ASSIST). We did not, however, examine the CAGE questionnaire, despite its fairly widespread use in clinical trials of alcohol treatment, since it is not sensitive to lower-level hazardous use and has not performed well with adolescents and young adults.^83,^ ^84^ We did not limit evidence related to benefits or harms of unhealthy alcohol screening or treatment (KQs 1 and 3–5) on the basis of the screening instruments used in those studies; any screening instrument was accepted for these KQs.

To be included in this review, test performance (KQ2) studies were required to evaluate their screening tests against a reference standard, rather than another screening instrument. For reference standards, we accepted structured or semistructured interviews assessing AUD and/or detailed quantity and frequency assessment, or computer-based versions of structured assessments of either AUD or detailed alcohol quantity and frequency assessments. In addition, we excluded studies that assembled “clean” case and control groups, such as individuals being treated for AUD (cases) and a community sample with no history of alcohol treatment (controls).

Intervention studies (KQs 1, 3, 4, 5) were required to report alcohol use as an outcome, such as frequency and/or quantity of use, abstinence, score on an instrument measuring severity of unhealthy use, or meeting criteria for AUD. We required a minimum of 6 months of followup for all populations except pregnant women, who had no minimum followup requirement. We included interventions that were conducted in or recruited from primary care or a health care system or that we judged could feasibly be implemented in or referred from primary care. Eligible settings included primary care clinics; prenatal clinics; obstetrics/gynecology clinics; specialty medical treatment settings (e.g., diabetes management, dialysis clinics); and research clinics/offices, homes, or other community settings, including electronic or computer-based screening. For KQs 4 and 5, we required that screening to identify eligible participants must have taken place in settings comparable to primary care with a defined population (e.g., primary care clinic; Special Supplemental Nutrition Program for Women, Infants, and Children; college freshmen orientation). Screening that took place in behavioral/mental health clinics, substance abuse treatment centers, emergency department/trauma centers, worksites (including occupational screening), inpatient/residential facilities, or other institutions (e.g., correctional facility) were excluded. We focused on studies of counseling to reduce unhealthy alcohol use, with or without referral, and were open to a variety of approaches (e.g., brief advice, personalized normative feedback, motivational interviewing, cognitive behavioral therapy), strategies (e.g., action plans, diaries), delivery methods (e.g., face-to-face, electronic), length of contact (e.g., brief, extended), providers (e.g., medical, health educators, peers), and number of contacts (e.g., single, multiple). Interventions to prevent initiation of use among nonusers were not included. Since pharmacotherapy is primarily relevant to patients with severe AUD, studies of pharmacotherapy treatment were excluded.

Two reviewers independently reviewed titles and abstracts for potential inclusion, then two reviewers reviewed the full-text articles. Discrepancies were resolved via discussion and third-party consultation as needed. Title, abstract, and full-text review were conducted in DistillerSR (Evidence Partners, Ottawa, Canada).

## Quality Assessment and Data Abstraction

Two reviewers applied USPSTF design-specific criteria (Appendix A Table 3)^85^ and supplemented it with criteria from the Quality Assessment of Diagnostic Accuracy Studies^86^ to assess the methodological quality of all eligible studies. We assigned each study a quality rating of “good,” “fair,” or “poor.” Discordant quality ratings were reviewed and discussed; a third reviewer adjudicated as needed. Studies rated as poor quality were excluded from the review.

For intervention trials, good-quality studies were those that met all or nearly all of the specified quality criteria (e.g., comparable groups were assembled initially and maintained throughout the study, and followup was ≥90%), whereas fair-quality studies did not meet all of these criteria but did not have serious threats to their internal validity related to the design, execution, or reporting of the study. Intervention studies rated as poor quality generally had several important limitations, including at least one of the following risks of bias: very high attrition (generally >40%), differential attrition between intervention arms (generally >20%); lack of baseline comparability between groups without adjustment; or issues in trial conduct, analysis, or reporting of results that put the validity of the findings in doubt (e.g., possible selective reporting, inappropriate exclusion of participants from analyses, and questionable validity of randomization and allocation concealment procedures). For studies of test performance, good-quality studies recruited patients consecutively or randomly; administered the index test blinded to, or at least prior to, the reference standard; used a reference standard that could accurately classify the target condition; interpreted the reference standard independently from the screening test; and administered the screening test and reference standard on the same day to all participants.

For all of the included studies, one reviewer extracted key elements into standardized abstraction forms in DistillerSR. A second reviewer checked the data for accuracy. For each study, we abstracted general characteristics of the study (e.g., author, year, study design), clinical and demographic characteristics of the sample and setting (e.g., age, race/ethnicity, baseline clinical characteristics, setting, country), analytic methods, and results.

For test accuracy studies (KQ2), we abstracted details of the reference standards and screening instruments. We abstracted the optimal cutoff for each screening test, either as defined by the author or selected by the reviewer as the best balance of sensitivity and specificity reported. We also abstracted the cutoff of 8 or higher for AUDIT; 3 or higher, 4, and 5 for AUDIT in U.S. primary care studies; 3 or higher for AUDIT-C in women; and 4 or higher for AUDIT-C in men. The outcomes of interest were sensitivity and specificity, which we calculated based on provided 2×2 tables if they were not directly reported.

For intervention characteristics of KQ 4 and 5 trials, we abstracted detailed information about specific components: setting, mode of delivery (i.e., in-person, telephone, electronic, or print); therapeutic or intervention approach (e.g., cognitive behavioral therapy, motivational interviewing), duration, number, and length of sessions; providers and provider training; and adherence. We determined the intensity of the intervention based on the number and length of contacts and assigned one of the following designations: very brief (single contact, ≤5 minutes), brief (single contact, ≤15 minutes), extended (single contact, >15 minutes), brief multicontact (multiple contacts, ≤15 minutes each), or extended multicontact (multiple contacts, one or more of them >15 minutes).

## Data Synthesis and Analysis

We created summary tables for all KQs showing study, population, and intervention characteristics (if applicable) and outcomes for qualitative evidence synthesis. Studies were grouped according to population: adolescents (ages ~12 to 18 years), young adults (ages ~18 to 25 years), general adult populations (age ≥18 years), older adults (age ~≥65 years), and pregnant and postpartum women. We used these tables along with forest plots of results to examine data for consistency, precision, and, for intervention trials, the relationship of effect size with key potential modifiers such as population, treatment contact time, control group alcohol use at baseline, and publication date. If available, we abstracted and examined results reported in the following subgroups: sex, age, race/ethnicity, socioeconomic status group, pregnant women, and those with specific concurrent substance use, specific severity of disorder, mental health condition, or at a particular level of readiness to change.

For studies on the accuracy of screening instruments (KQ2), we calculated confidence intervals (CIs)^87,^ ^88^ in Stata, version 13.1 (Stata Corp LP, College Station, TX), using data from contingency tables that included true positives, false positives, false negatives, and true negatives. If these data were not reported directly, we created contingency tables based on the total sample size, number of persons with the condition according to the reference standard, sensitivity, and specificity. No pooled analyses were performed due to the small number of studies that were available for each combination of study populations, screening tests, reported screening test cutoffs, and target conditions. We report a range of sensitivity and specificity across eligible studies to provide an overall description of findings. While many conditions were reported in our included studies, we focused our analysis on a) the full spectrum of unhealthy use (including use in pregnant women) and b) use disorder (DSM-IV abuse and dependence, or DSM-5 use disorder). Our primary analyses focused on the full spectrum of unhealthy use (assessing for exceeding limits, abuse, or dependence), although we also report data on exceeding limits alone in the detailed results. Data for other conditions, including dependence only (DSM-IV dependence or DSM-5 moderate/severe dependence), are in Appendix G and Appendix I.

For KQ4, we selected drinks per week as our primary outcome since it was by far the most commonly reported outcome. We converted all related outcomes to drinks per week, such as when provided with other time frames (e.g., drinks/month) or with grams of ethanol rather than drinks. We used the conversion factor of 14 g of ethanol for one standard drink, since this is the definition of a standard drink in the United States.

We had sufficient data with acceptable comparability between studies to conduct meta-analysis with 40 trials altogether, across the four main alcohol-use outcomes of drinks per week, exceeding recommended limits, heavy use episodes, and abstinence (for pregnant women). Few health outcomes were reported in enough trials to consider pooling; however, we were able to conduct a meta-analysis of mortality and alcohol problems or consequences.

We ran random-effects models using the DerSimonian and Laird pooled estimate, which we felt was acceptable because most analyses either included more than 10 trials or had low statistical heterogeneity.^89^ For analyses that showed statistically significant pooled effects but had fewer than 10 trials and I^2^ greater than 50 percent, we also ran a sensitivity analysis, using a more conservative profile likelihood model to see if statistical significance was sustained. If the profile likelihood model did not converge, we ran a restricted maximum likelihood analysis with the Knapp-Hartung correction for small samples. When trials only reported results separately for subgroups (e.g., males and females), we included entries for both subgroups in the meta-analysis. For outcomes with 10 or more trials in the meta-analysis (drinks per week, exceeding recommended limits, and heavy use episodes), we generated funnel plots and ran Egger’s test to examine funnel plot asymmetry to explore small study effects, which can be an related to publication bias.^90^ Additionally, for drinks per week, which included 31 trials (and 36 separate entries) and had considerable statistical heterogeneity (I^2^=64%), we conducted meta-regression and sensitivity analyses to explore factors that were associated with effect size. We used Stata version 13.1 for all analyses.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach,^91^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation Working Group.^92^ Our method explicitly addresses four of the five domains required by the Evidence-based Practice Center: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there was insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body of evidence limitations field highlights important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Two independent reviewers rated each KQ according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

The draft Research Plan was posted for public comment on the USPSTF Web site from August 25, 2016, to September 21, 2016. In response to public comments, the USPSTF narrowed the scope of the review to target nondependent, unhealthy alcohol use. Based on this change, the USPSTF also modified the inclusion criteria to exclude test performance studies of the CAGE questionnaire (since it is not used for identifying the full spectrum of at-risk alcohol use) and pharmacotherapy intervention studies (since these are typically reserved for persons with alcohol dependence). In addition, the USPSTF revised the inclusion criteria to include studies limited to persons with concomitant, nonpsychotic mental health disorders such as depression and anxiety disorders. The USPSTF made other minor modifications and clarifications as appropriate, such as expanding some outcomes (“school/educational outcomes” rather than “school performance”), including the International Statistical Classification of Diseases code system as a way to identify persons with the condition, and noting that interventions to prevent initiation of alcohol use in adolescents are excluded. A final research plan was posted on the USPSTF’s Web site on October 20, 2016.

This full draft report was shared with invited expert reviewers and federal partners. We compiled the comments received from these invited experts and addressed them in the report when appropriate. Additionally, a draft of this report was posted for public comment on the USPSTF Web site from June 5 through July 5, 2018. A few comments were received during this public comment period; minor changes were made to the report based on these comments but no changes were made to the evidence or to our conclusions.

## USPSTF Involvement

We worked with six USPSTF members at key points throughout this review, particularly when determining the scope and methods for this review and developing the Analytic Framework and KQs. After revisions reflecting the public comment period, the USPSTF members approved the final analytic framework, KQs, and inclusion and exclusion criteria. The Agency for Healthcare Research and Quality funded this review under a contract to support the work of the USPSTF. An agency Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.