# Chapter 1 Introduction

## Condition Definition

Unhealthy alcohol use encompasses a wide range of behaviors, from drinking above the recommended limits (i.e., risky drinking) to severe alcohol use disorder (AUD). Types of unhealthy alcohol use and related terms are listed in Table 1 and are not mutually exclusive; for example, persons with AUD also meet criteria for harmful use. The National Institute on Alcohol Abuse and Alcoholism (NIAAA) recommends that men ages 21 to 65 years consume no more than 4 drinks per day (56 g/day, according to the U.S. standard of 14 g/drink) and no more than 14 drinks per week (196 g/day), based on the standard drink amount of a 12-oz beer (5% alcohol), 5 oz of wine (12% alcohol), or 1.5 oz of distilled spirits (40% alcohol).^1^ For women of any age and men age 65 years and older, the recommendation is to consume no more than three drinks per day and seven drinks per week (42 g/day or 98 g/week). Multiple organizations recommend no use of alcohol during pregnancy.^2–5^ The NIAAA guide for youth age 18 years and younger suggests criteria that vary by age: for example, for 12- to 15-year-olds, any drinking in the past year is considered moderate risk and drinking on 6 or more days in the past year is considered high risk; for 18-year-olds, 12 to 51 drinking days is considered moderate risk and 52 or more days is considered high risk.^6^ A person meets Diagnostic and Statistical Manual of Mental Disorders (DSM-5) criteria for AUD if they experience at least two of the 11 criteria listed in Appendix A Table 1; severity of the disorder is specified (mild, moderate, severe) and based on the number of criteria met. This is a change from previous versions of the DSM, which had separate diagnoses for alcohol abuse and alcohol dependence (Appendix A Table 1). DSM-5 severity modifiers of moderate or severe correspond to alcohol dependence in earlier versions of the DSM and the International Statistical Classification of Diseases and Related Health Problems system.

Table 1 Unhealthy Alcohol Use: Terms and Definitions

Term | Source | Definition
Low-risk use/Lower-risk use | ASAM^291^ | Consumption of alcohol below the amount identified as hazardous and used in situations not defined as hazardous.
Moderate use | USDA^32^ | For women: up to 1 drink per day For men: up to 2 drinks per day Should avoid alcohol completely: adolescents, women who are pregnant or trying to get pregnant, adults when planning to drive a vehicle or operate machinery, taking medication that interacts with alcohol, or if they have a medical condition that alcohol can aggravate.
Risky/At-risk use | NIAAA^1,^ ^6,^ ^292,^ ^293^ | Consumption of alcohol above recommended daily, weekly, or per occasion amounts, but not meeting criteria for alcohol use disorder. For women: no more than 3 drinks per day and no more than 7 drinks per week. For men: no more than 4 drinks per day and no more than 14 drinks per week. Should avoid alcohol completely: adolescents, women who are pregnant or trying to get pregnant, adults when planning to drive a vehicle or operate machinery, taking medication that interacts with alcohol, or if they have a medical condition that alcohol can aggravate. For adolescents, NIAAA defines moderate- and high-risk use based on days of alcohol use in the past year, by age group, as follows: Moderate risk: Age 12-15: 1 day/year Age 16-17: 6 days/year Age 18: 12 days/year Highest risk: Age 11: 1 day Age 12-15: 6 days Age 16: 12 days Age 17: 24 days Age 18: 52 days
Excessive use | CDC^294^ | Binge drinking, heavy drinking, and any alcohol use by people younger than age 21 years and by pregnant women Binge drinking: ≥5/4 drinks per occasion for men/women Heavy drinking: ≥15/8 drinks per week for men/women
Unhealthy use | ASAM^291^ | Any use that increases the risk or likelihood for health consequences (hazardous use [see below]), or has already led to health consequences (harmful use [see below])
Hazardous use | WHO^295^ | A pattern of substance use that increases the risk of harmful consequences for the user. In contrast to harmful use, hazardous use refers to patterns of use that are of public health significance despite the absence of a current alcohol use disorder in the individual user.
Hazardous use | ASAM^291^ | Alcohol use that increases the risk or likelihood of health consequences. This does not include alcohol use that has already led to health consequences.
Harmful use | WHO^296^ | A pattern of drinking that is already causing damage to health. The damage may be either physical (e.g., liver damage from chronic drinking) or mental (e.g., depressive episodes secondary to drinking). This is the description for ICD-10 code F10.1, which is also labeled “Alcohol Abuse” in the 2018 ICD-10-CM codebook.
Harmful use | ASAM^291^ | Consumption of alcohol that results in health consequences in the absence of addiction.
Alcohol use disorder | DSM-5^297^ | A maladaptive pattern of alcohol use leading to clinically significant impairment or distress, as manifested by two (or more) of the following, occurring within a 12-month period:; 1. Having times when the patient drank more, or longer, than intended.; 2. More than once wanted to cut down or stop, tried it, but could not.; 3. Spending a lot of time drinking or being sick/getting over the after effects of drinking.; 4. Wanting to drink so badly that they could not think of anything else.; 5. Found that drinking (or being sick from drinking) often interfered with taking care of home or family responsibilities, caused problems at work, or caused problems at school.; 6. Continuing to drink even though it was causing trouble with family and friends.; 7. Given up or cut back on activities that were important or interesting in order to drink.; 8. More than once gotten into situations while or after drinking that increased the chances of getting hurt (e.g., driving, swimming, unsafe sexual behavior).; 9. Continued to drink even though it was causing depression or anxiety, other health problems, or causing memory blackouts.; 10. Having to drink much more than previously in order to get the desired effect, or finding that the usual number of drinks had much less effect than previously.; 11. Experiencing the symptoms of withdrawal after the effects of alcohol were wearing off, such as trouble sleeping, shakiness, restlessness, nausea, sweating, racing heart, or seizure.; Severity is determined based on the number of symptoms present:; - Mild: 2-3 symptoms; - Moderate: 4-5 symptoms; - Severe: 6 or more symptoms
Binge drinking/heavy drinking episodes^*^ | NIAAA^292,^ ^293^ | A pattern of drinking that brings blood alcohol concentration levels to 0.08 g/dL. This typically occurs after 4 drinks for women and 5 drinks for men—in about 2 hours.
Binge drinking/heavy drinking episodes^*^ | SAMHSA^298^ | Drinking 5 or more alcoholic drinks on the same occasion on at least 1 day in the past 30 days.
Heavy drinking | SAMHSA^298^ | Drinking 5 or more drinks on the same occasion on each of 5 or more days in the past 30 days.
Alcohol dependence | WHO/ICD-10-CM^299^ | Three or more of the following at some time during the previous year:; 1. A strong desire or sense of compulsion to take the substance; 2. Difficulties in controlling substance-taking behavior in terms of its onset, termination, or levels of use; 3. A physiological withdrawal state when substance use has ceased or been reduced, as evidenced by: the characteristic withdrawal syndrome for the substance; or use of the same (or a closely related) substance with the intention of relieving or avoiding withdrawal symptoms; 4. Evidence of tolerance, such that increased doses of the psychoactive substance are required in order to achieve effects originally produced by lower doses (clear examples of this are found in alcohol- and opiate-dependent individuals who may take daily doses sufficient to incapacitate or kill nontolerant users); 5. Progressive neglect of alternative pleasures or interests because of psychoactive substance use, increased amount of time necessary to obtain or take the substance or to recover from its effects; 6. Persisting with substance use despite clear evidence of overtly harmful consequences, such as harm to the liver through excessive drinking, depressive mood states consequent to periods of heavy substance use, or drug-related impairment of cognitive functioning; efforts should be made to determine that the user was actually, or could be expected to be, aware of the nature and extent of the harm

* According to ASAM^291^ the preferred term is a heavy drinking episode.

Abbreviations: ASAM = American Society of Addiction Medicine; DSM-5 = Diagnostic and Statistical Manual of Mental Disorders; NIAAA = National Institute on Alcohol Abuse and Alcoholism; SAMHSA = Substance Abuse and Mental Health Services Administration; WHO = World Health Organization; ICD-10-CM = International Classification of Diseases-10-Classification of Mental and Behavioral Disorders.

Defining unhealthy levels of drinking is complex and challenging. The primary evidence informing the established cut-points comes from epidemiological evidence and studies of adults providing dose-response curves, which involve nuanced interpretation.^7,^ ^8^ The primary challenge in setting these limits is determining the threshold that divides “low risk” and “high risk” drinking. These interpretations rely on decisions regarding what level of harm has substantial enough magnitude to warrant caution, as well as what types of harms should be considered. As a result, there is no firm consensus worldwide regarding the definition of risky drinking, and the definition of a standard drink varies between nations.^7^

## Prevalence

Unhealthy alcohol use is relatively common and is increasing in adults.^9^ Based on the 2016 Behavioral Risk Factor Surveillance System (BRFSS) Survey, 6.5% of adults reported drinking above recommended levels (≥14/7 drinks per week for men/women).^10^ In addition, according to data from the 2016 National Survey on Drug Use and Health (NSDUH), an estimated 14.6 million adults met the criteria for having AUD, representing 7.8 percent of men and 4.2 percent of women.^11^ Prevalence figures by age are shown in Table 2. Among adults age 18 years and older, 26.2 percent reported heavy use episodes (≥5 drinks on the same occasion on ≥1 day in the previous month, also referred to as binge episodes) and 6.6 percent reported engaging in heavy drinking (≥5 drinks on the same occasion on ≥5 days) in the previous month.^11^ Additionally, 9.2 percent of adolescents, ages 12 to 17 years, reported being current alcohol users and 4.9 percent reported heavy use episodes in the previous month. Furthermore, an estimated 488,000 (2.0%) adolescents were reported to have AUD, representing 2.4 percent of females and 1.5 percent of males.^11^ Among college students (regardless of age), 57.2 percent reported any past-month alcohol use, 38.0 percent reported past-month heavy use episodes, and 10.5 percent reported past-month heavy alcohol use.^11^ Rates of AUD are lower for older adults (1.6%), as are rates of having heavy use episodes in the past month (9.7%) and past-month heavy alcohol use (2.3%).

Table 2 Prevalence of Selected Types of Unhealthy Alcohol Use and Any Alcohol Use in the United States, 2016 National Survey on Drug Use and Health^11^

Population | % Heavy use episode, past month^*^ | % Heavy drinking, past month^†^ | % Alcohol use disorder, current | % Alcohol use, past month
Adolescents | 4.9 | 0.8 | 2.0 | 9.2
Adults (18+) | 26.2 | 6.6 | 6.0 | 55.0
Young adults (18-25) | 38.4 | 10.1 | 10.7 | 57.1
Middle adults (26+) | 24.2 | 6.0 | 5.2 | 54.6
Older adults (65+) | 9.7 | 2.3 | 1.6 | 42.6
Pregnant women | 4.3 | 0.9 | ^‡^ | 8.3

* ≥5 drinks on one occasion in the past month.

† ≥5 drinks on one occasion at least 5 times in the past month.

‡ Data not available.

According to the National Epidemiologic Survey on Alcohol and Related Conditions (NESARC), high-risk drinking increased by 29.9 percent between 2001–2002 and 2012−2013 among adults in the United States.^9^ Increases were particularly pronounced among women (57.9% increase), nonwhites (40.3% to 62.4% increases), and older adults (65.2% increase).^9^ Similarly, the prevalence of AUD increased from 8.5 to 12.7 percent, a 35.7 percent increase. The largest increases were seen in women (59.8% increase), blacks (55.8% increase), and adults age 45 years and older (61.9% to 75.0% increases).^9^ It is unclear why the NESARC identified substantially higher AUD prevalence than the NSDUH cited above, but the NESARC methods were almost identical across survey years, so the trend over time is likely reliable. Further, its finding of increased prevalence of unhealthy use over time is supported by similar trends seen in other large-scale national surveys, for both general and older adult populations.^12–14^ Interestingly, however, the NSDUH data show a declining trend in the proportion of adolescents reporting alcohol use in the previous month, and slight reductions between 2015 and 2016 on unhealthy use in adults, so it is unclear whether the rising trend has continued beyond 2012–2013.^15^ Reviewers have noted that declining sex differences in prevalence of alcohol use likely reflect changes in sociocultural environments, and that countries with rising alcohol use rates are showing smaller sex differences in rates of alcohol use, earlier onset of alcohol use, and earlier development of AUD symptoms in younger cohorts compared with older cohorts.^16^

Disparities exist among racial/ethnic minorities and underserved populations in terms of the prevalence of AUD and overall drinking patterns, as well as adverse health effects and consequences related to heavy alcohol use. The recent publication analyzing NESARC data from 2012 to 2013 referenced above found that the odds of developing an AUD of any severity in the previous 12 months was significantly higher among men (adjusted odds ratio [adjOR], 1.9 [95% confidence interval {CI}, 1.72 to 2.01]) versus women, and individuals living in urban cities (adjOR, 1.4 [95% CI, 1.20 to 1.55]) versus rural environments.^17^ A greater percentage of Native Americans (19.2%) reported AUD of any severity in the previous 12 months followed by blacks (14.4%) and whites (14.0%), but the difference in prevalence between races/ethnicities was not found to be significant. That same trend was seen among persons with family incomes less than $20,000 per year (16.2%) versus those of higher socioeconomic status (12.7% to 14.0%).^17^ Drinking patterns have also been found to vary by race/ethnicity, with Hispanics (17.2%) being shown to have the highest prevalence of binge drinking, followed by blacks (15.6%) and whites (14.8%).^18^ Additionally, Hispanic men are reported to have a higher drink maximum in a day (7.4) compared with white (7.0) and black (4.9) men.^19^ Although Native Americans have been shown to have higher rates of heavy and binge drinking compared with other races/ethnicities, recent evidence has been mixed.^20^

## Burden

Excessive alcohol use is one of the leading causes of premature mortality and is responsible for 1 in 10 deaths among working-age adults ages 20 to 64 years in the United States.^21^ From 2006 through 2010, the number of average annual alcohol-attributable deaths in the United States were 87,798 (27.9/100,000 population), with an estimated 2.5 million years of potential life lost.^21^ Overall, 44 percent of these deaths were due to chronic conditions (e.g., alcoholic liver disease) and 56 percent were due to acute conditions (e.g., motor vehicle traffic crashes). In 2013, there were 29,001 deaths directly related to alcohol use, which does not include mortality from unintentional injuries, homicides, and other causes indirectly related to alcohol use.^22^ In the United States, 3.2 to 3.7 percent of cancer deaths (182,000 to 213,000 deaths) are attributed to alcohol use, including cancers of the breast, oral cavity and neck, and gastrointestinal sites.^23^ Men are more likely to die from alcohol-related causes than women—the age-adjusted death rate was 2.9 times higher in men than in women in 2013.^22^ Additionally, 5.1 percent of the global burden of disease and injury in disability-adjusted life years was related to alcohol.^24^

Consuming alcohol while pregnant can result in fetal alcohol spectrum disorders, as well as additional adverse birth outcomes, making alcohol use throughout pregnancy a major preventable cause of birth defects and developmental disabilities.^25^ Prenatal exposure to alcohol can affect the developing brain, heart, kidney, liver, gastrointestinal tract, and endocrine systems.^26^ Data from the 2011 to 2013 BRFSS survey showed that 1 in 10 pregnant women ages 18 to 44 years reported consuming alcohol in the previous month and 3.1 percent participated in binge drinking.^25^ Beyond the harmful effect of alcohol use during pregnancy, evidence shows that women who engage in unhealthy alcohol use are more susceptible to the deleterious health effects, including liver and cognitive effects, than men who engage in unhealthy alcohol use. These effects may be mediated by the effects of alcohol on sex hormones and in alcohol pharmacokinetics’ effect on the brain.^16^

College students’ health also suffers with unhealthy alcohol use. For example, an estimated 1,825 college students ages 18 to 24 years have died annually from alcohol-related, unintentional injuries, including motor vehicle crashes.^27,^ ^28^ Approximately 696,000 students ages 18 to 24 years were assaulted by another student who had been drinking, and 97,000 students ages 18 to 24 years report experiencing alcohol-related sexual assault or date rape.^27,^ ^29^ About 1 in 4 college students report academic consequences from drinking, including missing class, falling behind in class, doing poorly on examinations or papers, and receiving lower grades overall.^27,^ ^30^

In 2010, excessive alcohol use was estimated to cost the United States $249 billion, with State and Federal governments paying $100.7 billion, or just over 40 percent of these costs.^31^ The majority of the cost of excessive alcohol use was due to binge drinking (76.7%), while underage drinking accounted for 9.7 percent, and drinking while pregnant was 2.2 percent ($5.5 billion) of the total cost. The majority of the economic cost of excessive alcohol use is due to losses in workplace productivity (72%), followed by health care expenses (11%), law enforcement and criminal justice expenses (10%), and losses from motor vehicle crashes (5%).^31^ These estimates are thought to be underestimates, however, due to the fact that information on alcohol is typically underreported or unavailable. Additional costs, including pain and suffering due to alcohol-related injuries and alcohol-related morbidities, are not included.

U.S. national drinking guidelines^6,^ ^32^ are consistent with the evidence on risk levels reported in meta-analyses of observational literature. One meta-analysis found that the average daily volume at which an increased risk of all-cause mortality occurs is approximately 38 g of ethanol (2.7 drinks, according to the U.S. standard),^33^ and appears to be lower for women than for men. In addition, the risk of liver disease and a number of cancers (primarily of the gastrointestinal tract, liver, and breast) are increased at an average daily volume of approximately 25 g (1.8 drinks per day).^8,^ ^34^ A more detailed discussion of the epidemiology of the health effects of alcohol use is in Appendix B.

In addition to disparities in the prevalence of AUD and drinking patterns, disparities are also found in alcohol-related social and health problems. Data from the NSDUH show that whites and Native Americans report the highest rates of driving under the influence in the previous year, with 15.6 percent of whites and 13.3 percent of Native Americans reporting this activity.^35^ Research has also shown that the rates of alcohol-attributed violence and intimate partner violence (IPV) vary by race/ethnicity. A study by Schafer and colleagues found that the reporting of unhealthy alcohol use increased the risk of IPV in black couples compared with white and Hispanic couples.^36^ Alcohol use has also been found to contribute to victimization among Native Americans, with numerous studies reporting that Native Americans are at greater risk of alcohol-related trauma (IPV, rape, and assault) compared with other racial/ethnic groups in the United States.^37,^ ^38^ Alcohol-related morbidity and mortality are also found to vary across racial/ethnic groups. Hispanics and blacks have been shown to have a greater risk of developing liver disease compared with whites, and Hispanic men are reported to have the highest incidence of liver cirrhosis mortality compared with other races/ethnicities.^39,^ ^40^ Further, the incidence of alcohol-related esophageal cancer and pancreatic disease are higher for black men than white men, and fetal alcohol syndrome and fetal alcohol spectrum disorders are more prevalent in blacks and Native Americans.^41–43^ A review of peer-reviewed and national surveillance reports found that Native Americans experience the highest rates of alcohol-attributable motor vehicle crash mortality, suicide, and falls compared with other racial/ethnic groups.^44^

## Risk Factors and Etiology for AUD

Excessive use of alcohol can affect neurobiological functioning in the basal ganglia, extended amygdala, and prefrontal cortex, leading to the development of alcohol tolerance (needing larger amounts to feel “high”), diminution of pleasure from everyday human activities such as food and social interaction, increased release of neurotransmitters associated with stress when alcohol is absent from the body, and ultimately addiction.^45^ Not surprisingly, initiation of drinking at younger ages, when the brain is rapidly developing and changing, is associated with an increased risk of unhealthy alcohol use. For example, an analysis of the 2010 NSDUH data found that younger age at first use of alcohol was associated with increased likelihood of reporting a heavy use episode in the past month.^46^ Similarly, NESARC found that the odds of developing alcohol dependence are 2.3 times higher when initiation of alcohol use occurs prior to age 15 years, compared with initiation after age 18 years (adjOR, 2.33 [95% CI, 1.74 to 3.13]), with similar results for alcohol abuse.^47^ Additionally, childhood maltreatment, specifically sexual abuse and/or physical abuse, increases the risk of developing AUD.^48–51^ For example, a 2016 study of young adults (n=300) found that childhood physical abuse (age ≤18 years) more than doubled the odds of AUD in young adulthood (adjOR, 2.41 [95% CI, 1.31 to 4.45]; p<0.01).^48^

AUD commonly co-occurs with personality and mood disorders,^52,^ ^53^ although the causal relationship between them is unclear and likely variable. Parental history of an AUD increases the risk of AUD in their children. The Copenhagen Perinatal Cohort study (n=9,125) found that offspring of parents with an AUD have approximately twice the odds of developing an AUD, compared with offspring of parents without an AUD.^54^ Another population-based cohort study (n=398,881) found that the risk for offspring developing an AUD increased when one or both parents had the disorder (adjusted hazard ratio, 1.44 [95% CI, 1.29 to 1.61] and 2.29 [95% CI, 1.64 to 3.20] for persons with one and both parents with an AUD, respectively).^55^

A study of twins suggests that risk factors for AUD may differ between men and women.^56^ The study found that, for women, family history of AUD, early-onset anxiety disorder, and nicotine dependence were strong risk factors for AUD. In men, important risk factors included novelty seeking, conduct disorder, childhood sexual abuse, parental loss, neuroticism, low self-esteem, and low marital satisfaction.

## Rationale for Screening

While persons with severe AUD are likely to be identified through the health and social effects of their alcohol use, those with lower levels of unhealthy alcohol use may not be easily identifiable without direct questioning. Yet unhealthy alcohol use affects a wide range of medical conditions that are commonly encountered in the primary care setting, including (but not limited to) gastrointestinal, cardiopulmonary, dermatological, reproductive, and neurological conditions.^57^ Further, alcohol interacts dangerously with many commonly used prescription and over-the-counter medications.^58^ Because of these factors, patients’ alcohol use can have a substantial effect on their treatment for and recovery from many (if not most) conditions that are addressed in primary care, and efforts to reduce unhealthy alcohol use have substantial potential to improve the health of primary care patients. If screening and counseling can reduce alcohol use to within recommended limits, such health effects could possibly be avoided. Further, screening and intervention for lower levels of unhealthy alcohol use in adolescents and younger adults, before their neurochemistry has been affected by chronic or heavy use, offer an important opportunity to avoid progression to more serious and likely difficult-to-treat levels of use.

The 2016 U.S. Surgeon General report has identified screening in health care settings as an important vehicle for identifying persons with unhealthy alcohol and substance use,^45^ and primary care–based alcohol screening and counseling were among the highest-rated preventive services in terms of clinically preventable burden in a study exploring health impact and cost-effectiveness of preventive clinical services.^59^ To further support screening and interventions in primary care settings, patients have expressed a preference for treatment in primary and collaborative care settings, rather than specialty settings.^60^

## Screening Strategies

Primary care practitioners have limited time to interact with their patients; therefore, brief or self-administered screening tests that identify the full spectrum of alcohol use are preferable to elaborate tools that occupy more clinician time.^61^ Numerous brief instruments have been developed (Appendix C); however, only a few have gained widespread use in clinical or research settings. For patients screening positive on a brief screener, followup questions are needed to confirm the presence of unhealthy use, assess the extent of unhealthy alcohol use, and help the patient and clinician determine appropriate next steps. Several clinician guides (Table 3) have been developed that lay out next steps after the initial assessment, which may include brief counseling, followup visits with the primary care clinician, a thorough assessment by an addiction medicine or mental health specialist, referral to community and specialty services, and medication.

Table 3 Published Clinical Guidance Documents From Major Health Organizations

Organization Year published | Guide | Screening tool recommended | Intervention approach | Other materials
NIAAA 2005 | Helping Patients Who Drink Too Much: A Clinician’s Guide | Single-item screener: How many times in the past year have you had 4/5 [F/M] or more drinks in a day? (Plus prescreen asking if they sometimes drink beer, wine, or other alcoholic beverages) | - Assess for use disorders; - Advise and Assist (separate pathways for patients with and without an alcohol use disorder): state conclusions and recommendations, gauge readiness to change, approach/discussion points provided based on readiness to change; - Followup: Continued discussions and support at subsequent visits, emphasizes empathy, supporting positive change; revisit goals/plan, engage others, consider referrals, address coexisting conditions, coordinate care | Clinician guide on medication for alcohol dependence, Patient education materials, Links/lists of other resources
NIAAA 2011 | Alcohol Screening and Brief Intervention for Youth: A Practitioner’s Guide | Two age-specific items about friends’ drinking and patients’ drinking frequency | - Guide patients (nonusers): reinforce healthy choices, elicit/affirm reasons not to use alcohol, educate about effects of alcohol on health; - Assess risk level (users); - Advise and assist (users): Collaborate on personal goal and action plan; advise against drinking and driving and riding with someone who has been drinking; plan a full psychosocial interview; further approach/discussion points provided based on risk level; - Followup: Continued discussions and support at subsequent visits, emphasizes empathy, supporting positive change; revisit goals/plan, engage parents, consider referrals | Links/lists of additional resources for clinicians, patients, parents
CDC 2014 | Planning and Implementing Screening and Brief Intervention for Risky Alcohol Use | NIAAA single-item screener or USAUDIT-C (items 1-3 of the U.S. version of the AUDIT) | - Assess severity; - Provide feedback on alcohol use; - Listen for and reinforce change talk (e.g., explore pros and cons of alcohol use, assess readiness to change); - Advise, if patient agrees to hear your advice; - Provide options: discussion of goals, consider action plan, consider referrals, seek agreement for followup | Implementation plan, patient handouts, provider training materials, links/lists of additional resources
AAFP 2017 | Addressing Alcohol Use Practice Manual: An Alcohol Screening and Brief Intervention Program | Not specified | - Advise every risky drinker to reduce alcohol use or quit; - Assess whether the patient is willing to reduce use or quit; - Assist: If willing to change, develop personalized plan, consider referral; employ motivational interviewing techniques such as expressing empathy, supporting self-efficacy, pointing out previous successes, rolling with resistance, helping patients see the discrepancy between where they are and where they would like to be; - Arrange followup | Implementation plan, links/lists of additional resources
WHO 2010 | Brief Intervention, the ASSIST-Linked Brief Intervention for Hazardous and Harmful Substance Use: Manual for Use in Primary Care (addresses alcohol, tobacco, and other substances) | ASSIST | - Ask if patients are interesting in seeing screening results and provide feedback; - Advise to reduce risk associated with substance use, but allow patients to take responsibility for their choices; - Further discussion: how concerned about screening results, pros and cons of substance use, summarize and reflect, show concern and empathy; - Provide patient materials | Intervention guides for multiple scenarios (e.g., multiple substances, high risk and injecting clients, longer or recurrent visits)
NIDA 2012 | Screening for Drug Use in General Medical Settings: Resource Guide (addresses alcohol, tobacco, and other substances) | NIDA-modified ASSIST | - Assess risk level; - Advise: review feedback and provide advice to reduce use; - Assess the patient’s readiness to change; - Assist: help develop goal and action plan if patient will consider medication, consider referral; - Arrange: referrals (if any) and followup visit (within 1-2 weeks for moderate- and high-risk patients) | Sample action plan worksheet, links/lists of additional resources

Abbreviations: AAFP = American Academy of Family Physicians; ASSIST = Alcohol, Smoking and Substance Involvement Screening Test; AUDIT = Alcohol Use Disorders Identification Test; CDC = Centers for Disease Control and Prevention; F/M = females/males NIAAA = National Institute on Alcohol Abuse and Alcoholism; NIDA = National Institute on Drug Abuse; USAUDIT-C = United States Alcohol Use Disorders Identification Test – Consumption; WHO = World Health Organization.

The previous systematic review to support the 2013 U.S. Preventive Services Task Force (USPSTF) recommendation identified one- or two-item screeners such as the NIAAA-recommended Single Item Alcohol Screening Questionnaire (SASQ), the Alcohol Use Disorders Identification Test (AUDIT), and the AUDIT-Concise (AUDIT-C) as having the best accuracy to screen for any level of unhealthy alcohol use among adults. The SASQ asks, “How many times in the past year have you had 5 [for men]/4 [for women] or more drinks in a day?”, where one or more occasions in the previous year constitutes a positive screen. The AUDIT-C includes three items covering frequency of alcohol use, typical amount, and occasions of heavy use. The full AUDIT includes these three items, plus seven questions regarding signs of alcohol dependence and common problems associated with alcohol use (e.g., being unable to stop once you start drinking, needing a drink first thing in the morning). The U.S. Department of Veterans Affairs (VA) specifically recommends annual screening with the AUDIT-C and SASQ. The Cut down, Annoyed, Guilty, Eye-opener (CAGE) screener is another one developed to detect alcohol dependence rather than the full spectrum of unhealthy alcohol use,^61^ and was used for screening in multiple treatment trials included in the previous review.

Screening instruments have also been developed for special populations, including adolescents, older adults, and pregnant women. For adolescents, the NIAAA recommends two items, asking about the patient’s alcohol use and their friends’ use. The NIAAA also developed the related Brief Screener for Tobacco, Alcohol, and other Drugs (BSTAD) to use this approach to assess alcohol, tobacco, and drug use. Both the NIAAA and American Academy of Pediatrics name the Car, Relax, Alone, Forget, Family, Friends, Trouble (CRAFFT) screener as a useful screening tool for identifying risky substance use in adolescents, which assesses riding in or driving a car while intoxicated, use of alcohol or drugs to relax, use when alone, forgetting what you’ve done while intoxicated, having friends or family suggest you cut down, and getting into trouble while using alcohol or drugs.

The Comorbidity Alcohol Risk Evaluation Tool (CARET) was developed for older adults. The CARET is a briefer version of two relatively lengthy instruments (the Alcohol-Related Problems Survey [ARPS] and the Short-ARPS [shARPS]) included in the previous review and was found to have acceptable accuracy but low feasibility for routine screening in primary care. The CARET includes items about common medications and medical conditions that could interact with alcohol to further characterize the risky nature of alcohol use in older adults.

Four instruments have been specifically developed to screen for problematic alcohol use during pregnancy: Tolerance, Worried, Eye-openers, Amnesia, Cut down (TWEAK); Tolerance-Annoyed, Cut down, Eye opener (T-ACE); Past use, Pregnancy, use by Parents and Partners (4P’s Plus); and Normal drinker, Eye opener, Tolerance (NET). Of these, a previous review concluded that the TWEAK and T-ACE performed best for pregnant women, along with the AUDIT-C. The T-ACE is specifically mentioned in the American College of Gynecologists and Obstetricians’ recommendation on alcohol screening.

Finally, the World Health Organization (WHO) developed the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) to screen for substance use more broadly, covering unhealthy use of drugs and smoking as well as alcohol.^62^ It has been validated in adults (age ≥18 years) and shows good cross-cultural neutrality.

## Interventions for Unhealthy Alcohol Use

For persons with unhealthy drinking behavior who do not have an AUD, a brief intervention to increase the awareness of alcohol use and increase motivation to make behavioral changes in primary care may be sufficient, while those with AUD may need referral to more extensive treatment,^63^ possibly including medication-assisted treatment. Medications approved by the U.S. Food and Drug Administration for the treatment of unhealthy alcohol use are intended for persons diagnosed with an AUD and are generally used after they have achieved abstinence.^64^ These medications include acamprosate, disulfiram, and naltrexone, which aim to reduce symptoms of abstinence, create a physical reaction if alcohol is consumed, or block the rewarding effects of drinking.^64^

A number of health organizations have developed clinician guides for primary care–based interventions to reduce unhealthy alcohol use, some of which also provide implementation advice and planning documents (Table 3). Their approaches fall under the Screening, Brief Intervention, Referral, and Treatment (SBIRT) framework, and typically use the Ask, Advise, Assess, Assist, Arrange (5 A’s) mnemonic, either explicitly or implicitly. Organizations generally recommend a very brief one- to three-item screener, followed by more in-depth risk assessment among persons who screen positive. Once unhealthy alcohol use is identified, guides typically suggest providing feedback to patients on their alcohol use; advising patients to reduce their alcohol use; having a discussion with patients to understand their readiness to change and develop goals and an action plan, if they are willing; and arranging for followup. Guides typically incorporate motivational interviewing tools to help patients increase their readiness to change, such as open-ended questions, affirmation, reflective listening, and summaries, along with standard motivational techniques such as expressing empathy, supporting self-efficacy, pointing out previous successes, rolling with resistance, and helping patients see the discrepancy between where they are and where they want to be. One review provides important perspective and recommendations on potential adaptations to SBIRT interventions for culturally diverse populations.^65^ Beyond these clinician guides, counseling interventions have been developed that include a wide range of approaches (e.g., motivational enhancement therapy, cognitive behavioral therapy, 12-step), specific strategies (e.g., action plans, drinking diaries), delivery methods (e.g., face-to-face, Web-based, individual, group-based), length of contact (e.g., brief, extended), and number of contacts (single, multiple).^66^ NIAAA has developed an online resource to help individuals understand treatment options, find practitioners, and recognize signs of higher-quality care for AUD. This is a comprehensive and easy-to-use tool to help patients and their families navigate the often complicated process of finding and choosing a treatment option.^67^

## Current Clinical Practice in the United States

Despite current clinical recommendations for physicians to screen patients for unhealthy alcohol use and provide brief counseling to those engaging in unhealthy drinking behaviors, not all physicians report following these recommendations in their practices. A 2016 cross-sectional survey of New York primary care physicians and nonphysician providers (n=213) found that approximately half (57%) reported screening patients for substance use (drugs as well as alcohol).^68^ Further, 46 percent of respondents reported providing a brief intervention to patients who were found to meet criteria for unhealthy use and 47 percent gave a referral to treatment. In a survey of primary care residents, 60 percent reported that they “usually” or “always” screened patients for unhealthy alcohol use; however, only 19 percent used screening instruments capable of detecting heavy use episodes.^69^ When compared with physicians, nonphysician providers (i.e., nurse practitioners and physician assistants) felt less comfortable talking with their patients about alcohol and drug use (p=0.004), and were less likely to perform a brief intervention (52% vs. 32%; p <0.0005) or refer a patient to treatment (50% vs. 70%; p=0.001).^68^ Data from the patient perspective confirm that screening for unhealthy alcohol use is widely employed; 78 percent of patients reported that in the previous 2 years they were asked by a health care professional about their alcohol use, and 68 percent were asked how much alcohol they use, according to the BRFSS survey.^70^ However, only 15.7 percent of adult respondents reported having a discussion about their use of alcohol with their providers; counseling was more common among binge drinkers but still fairly low (25.4% had ever discussed it, 13.4% discussed it in the previous year).^71^ Even lower screening and counseling rates have been reported among young adults^72^ and women’s reproductive health clinicians.^73^

Physicians report a number of common barriers to achieving higher rates of screening patients for unhealthy alcohol use. These include not having enough time to conduct a further assessment and counseling in the event of a positive screen, lack of adequate training about how to properly screen patients, not feeling confident about being able to assist patients meeting the criteria for unhealthy use, not feeling comfortable discussing alcohol use with patients, not trusting that their patients would be honest about their alcohol use, and not feeling that available treatments were effective.^68,^ ^69,^ ^74^ Clinic staff have also reported concerns that screening would interfere with the clinic flow.^75^

## Recommendations of Others

Recommendations and statements from other organizations about screening and treatment for unhealthy alcohol use are summarized in Appendix D. The VA, Surgeon General, NIAAA, the Centers for Disease Control and Prevention, and the American Society of Addiction Medicine all agree with the 2013 USPSTF recommendation that adult patients should be routinely screened for at-risk drinking and brief counseling should be provided to patients who are found to have unhealthy alcohol use behaviors.^76–80^ Additionally, the NIAAA recommends medical management for adults with alcohol dependence. The American Academy of Pediatrics recommends that pediatricians increase their capacity in substance use detection, assessment, and intervention and that they be familiar with SBIRT practices.^81^ Both the American College of Gynecologists and Obstetricians and WHO recommend that all women should be screened both before pregnancy and in their first trimester of pregnancy via validated tools (e.g., TACE) and that providers should offer a brief intervention to all pregnant women using alcohol.^24,^ ^82^

## Previous USPSTF Recommendation

In 2013, the USPSTF recommended that clinicians screen adults age 18 years or older for alcohol misuse and provide brief behavioral counseling interventions to reduce alcohol misuse to those engaged in risky or hazardous drinking behaviors (B recommendation).^66^ The USPSTF concluded, however, that the evidence was insufficient to assess the balance of benefits and harms of screening and behavioral counseling interventions to reduce alcohol misuse in adolescents (I statement).