# Appendix J Ongoing Studies

Study reference Trial identifier | Study name | Location | Estimated n | Description | 2018 Status
NCT01881841 | Computer Adaptation of Screening, Brief MET Intervention to Reduce Teen Drinking | US | 150 | The goal of this project is to evaluate the feasibility, acceptability, and effect size of a new computerized Motivational Enhancement Therapy (cMET) intervention for alcohol-involved adolescents in primary care. | Ongoing: Est. Completion Date Aug 2017
NCT02642757 | Alcohol Brief Counseling in Primary Care | Chile | 262 | This study evaluates the effectiveness of a brief intervention for the reduction of alcohol use among risky alcohol users in primary care delivered by paramedics. | Completed. No published results yet.
NCT02860442 | Project Guard: Reducing Alcohol Misuse/Abuse in the National Guard | US | 750 | The overall goal for the study is to test the efficacy of a smartphone app which includes an alcohol brief intervention (SP-BI) versus an Enhanced Usual Care (EUC) condition for National Guard members in the State of Ohio who meet criteria for at-risk drinking in the previous 3 months. | Ongoing: Est. Completion Date Jun 2020
NCT02671019 | Effectiveness and Costs of Internet-based Treatment for Harmful Alcohol Use and Face-to-face Treatment in Addiction Care | Sweden | 350 | The purpose of this trial is to compare the effectiveness and costs of a five-module Internet-based treatment program (including therapist support) for harmful alcohol use with the effectiveness and cost of the same treatment content delivered face-to-face in specialized addiction treatment. | Ongoing: Est. Completion Date Nov 2019
NCT02645721 | Internet Based Cognitive Behavior Treatment for Alcohol Use Disorders (ICBT-AUD) | Sweden | 166 | The purpose of this study is to determine whether extensive internet based cognitive behavior treatment program with guidance is a more effective method to treat individuals with alcohol use disorders than a briefer cognitive behavior treatment program without guidance | Ongoing: Est. Completion Date Jun 2019
NCT02703116 | Reducing Hazardous Alcohol Use in Social Networks Using Targeted Intervention | US | 450 | The purpose of this study is to assess the feasibility, acceptability and test the initial efficacy of eSBI compared with a nutrition intervention for at-risk youth. | Ongoing: Est. Completion Date Jul 2019
NCT01797835 | Alcohol Screening in an Ethnically Diverse Sample of Adolescents in Primary Care | US | 1573 | The current study tests the new NIAAA screening guide questions, which ask about friend and adolescent drinking, to see how well these questions work to predict subsequent alcohol use, problems, and involvement in other risk behaviors, such as sexual risk-taking and delinquency. In addition, the investigators plan to provide a brief motivational intervention for some at-risk teens and see whether alcohol use differs for those teens who receive the intervention and those teens who receive enhanced usual care. | Ongoing: Est. Completion Date Aug 2018
NCT02584621 | Web-Based Adolescent Motivational Enhancement Study (Web-AME) | US | 150 | This study is a randomized controlled trial that compares the effectiveness of an electronic personalized health screening app incorporating motivational feedback (i.e. “Check Yourself”) to usual care among moderate to high risk alcohol users. | Ongoing: Est. Completion Date Feb 2017, no published results yet
NCT02337361 | Computerized Tool for Preventing Prenatal Drinking | US | 200 | The purpose of the study is to test the efficacy of an innovative, self-administered computerized screening and brief intervention (SBI) for drinking during pregnancy will be adapted for use with non-pregnant childbearing age women. | Ongoing: Est. Completion Date Aug 2018
NCT02187887 | Online Program for Young Adult Veteran Drinkers | US | 793 | The primary objective of the research study is to test the feasibility of a brief Internet-based intervention to reduce heavy alcohol use among young adult veterans of wars in Iraq and Afghanistan. | Ongoing: Est. Completion Date Apr 2016, no published results yet
NCT02834949 | Improving Brief Alcohol Interventions with a Behavioral Economic Supplement | US | 393 | The purpose of this study is to evaluate the efficacy of a Substance-Free Activity Session (SFAS) as a supplement to a brief motivation intervention (BMI) in reducing alcohol use and alcohol-related consequences in college students. | Ongoing: Est. Completion Date Aug 2017, no published results yet
NCT01400581 | Considering Healthier Drinking Options in Collaborative Care (CHOICE) | US | 304 | The proposed study will evaluate the effectiveness of a collaborative care intervention for evidence-based management of alcohol use disorders in primary care settings. | Completed. No published results yet.
NCT02978027 | Mentored Research on Improving Alcohol Brief Interventions in Medical Settings | US | 300 | The purpose of the study is to delineate the degree to which adding motivational interviewing components to a brief intervention for unhealthy alcohol use improves outcomes. | Ongoing: Est. Completion Date Sep 2017, no published results yet