# Appendix I Evidence Tables

Appendix I Table 1 Results of Test Accuracy Studies to Detect Unhealthy Alcohol Use Among Adolescents (KQ2)

Appendix I Table 2 Results of Test Accuracy Studies to Detect Alcohol Use Disorder Among Adolescents (KQ2)

Appendix I Table 3 Results of Test Accuracy Studies to Detect Adolescents Who Exceeded Various Alcohol Drinking Limits (KQ2)

Appendix I Table 4 Results of Test Accuracy Studies to Detect Adolescents Who Exceeded Various Alcohol Drinking Limits (KQ2)

Appendix I Table 5 Results of Test Accuracy Studies to Detect Other Alcohol Use Conditions Among Adolescents (KQ2)

Appendix I Table 6 Results of Test Accuracy Studies to Detect Unhealthy Alcohol Use Among Young Adults (KQ2)

Appendix I Table 7 Results of Test Accuracy Studies to Detect Alcohol Use Disorder Among Young Adults (KQ2)

Appendix I Table 8 Results of Test Accuracy Studies to Detect Alcohol Dependence Among Young Adults (KQ2)

Appendix I Table 9 Results of Test Accuracy Studies to Detect Other Alcohol Use Conditions Among Young Adults (KQ2)

Appendix I Table 10 Results of Test Accuracy Studies to Detect Unhealthy Alcohol Use Among Adults (KQ2)

Appendix I Table 11 Results of Test Accuracy Studies to Detect Alcohol Use Disorder Among Adults (KQ2)

Appendix I Table 12 Results of Test Accuracy Studies to Detect Alcohol Dependence Among Adults (KQ2)

Appendix I Table 13 Results of Test Accuracy Studies to Detect Adults Who Exceeded Various Alcohol Drinking Limits (KQ2)

Appendix I Table 14 Results of Test Accuracy Studies to Detect Other Conditions Among Adults (KQ2)

Appendix I Table 15 Results of Test Accuracy Studies to Detect Unhealthy Alcohol Use Among Older Adults (KQ2)

Appendix I Table 16 Results of Test Accuracy Studies to Detect Alcohol Use Disorder Among Older Adults (KQ2)

Appendix I Table 17 Results of Test Accuracy Studies to Detect Alcohol Dependence Among Older Adults (KQ2)

Appendix I Table 18 Results of Test Accuracy Studies to Detect Any Alcohol Use Among Pregnant Women (KQ2)

Appendix I Table 19 Results of Test Accuracy Studies to Detect Alcohol Use Disorder Among Pregnant Women (KQ2)

Appendix I Table 20 Results of Test Accuracy Studies to Detect Alcohol Dependence Among Pregnant Women (KQ2)

Appendix I Table 21 Trial Recruitment Methods and Baseline Substance-Related Variables, by Subpopulation (KQ4)

Appendix I Table 22 Intervention Characteristics of All Trials, by Subpopulation (KQ4)

Appendix I Table 23 Intervention Details of All Trials (KQ4)

Appendix I Table 24 Dichotomous Outcome Exceeds Drinking Limits, by Outcome Type and Subpopulation (KQ4)

Appendix I Table 25 Dichotomous Heavy Use Episodes, by Subpopulation (KQ4)

Appendix I Table 26 Other Dichotomous Drinking and Behavioral Outcomes, by Subpopulation (KQ4)

Appendix I Table 27 Drinks per Week, by Subpopulation (KQ4)

Appendix I Table 28 Heavy Use Episodes per Week, by Subpopulation (KQ4)

Appendix I Table 29 Drinks per Drinking Day, by Subpopulation (KQ4)

Appendix I Table 30 Other Continuous Drinking Outcomes, by Subpopulation (KQ4)

Appendix I Table 31 Continuous Nondrinking Behavioral Outcomes, by Subpopulation (KQ4)

Appendix I Table 32 All-Cause Mortality Outcomes (KQ4)

Appendix I Table 33 Other Dichotomous Health Outcomes, by Outcome Type and Subpopulation (KQ4)

Appendix I Table 34 Continuous Health Outcomes, by Outcome Type and Subpopulation (KQ4)

Appendix I Table 35 Harms Outcomes, by Outcome Type and Subpopulation (KQ4)