# Appendix H Additional Figures

Appendix H Figure 1 Sensitivity and Specificity of the AUDIT at the Optimal* Cutoff to Detect Unhealthy Alcohol Use

This figure shows the sensitivity and specificity of the AUDIT at the optimal* cutoff to detect unhealthy alcohol use.

* Optimal cutoffs could vary by study and were selected as either the optimal cutoff determined by the authors or the reviewers.

Note: Degernhardt et al.^108^ did not provide confidence intervals and is not in the figure (adult males, cutoff ≥11: sensitivity =0.784, specificity=0.755; adult females, cutoff ≥9: sensitivity=0.681, specificity=0.864.

Abbreviations: AUDIT = Alcohol Use Disorders Identification Test; CI = confidence interval; n = number of participants analyzed.

Appendix H Figure 2 Sensitivity and Specificity of the AUDIT-C at Cutoff of ≥4 to Detect Unhealthy Alcohol Use Among Males

This figure shows the sensitivity and specificity of the AUDIT-C at a cutoff of ≥4 to detect unhealthy alcohol use among males.

Abbreviations: AUDIT-C = Alcohol Use Disorders Identification Test, Consumption; CI = confidence interval; n = number of participants analyzed.

Appendix H Figure 3 Sensitivity and Specificity of the AUDIT at Cutoff of ≥8 to Detect Unhealthy Alcohol Use Among Adolescents, Young Adults, Adults, and Older Adults

This figure shows the sensitivity and specificity of the AUDIT at a cutoff of ≥8 to detect unhealthy alcohol use among adolescents, young adults, adults, and older adults.

Abbreviations: AUDIT = Alcohol Use Disorders Identification Test; CI = confidence interval; n = number of participants analyzed

Appendix H Figure 4 Sensitivity and Specificity of the AUDIT at Cutoffs of ≥3, 4, 5 in U.S. Primary Care

This figure shows the sensitivity and specificity of the AUDIT at cutoffs of ≥3, 4, and 5 to detect unhealthy alcohol use in U.S. primary care

Abbreviations: AUDIT = Alcohol Use Disorders Identification Test; CI = confidence interval; n = number of participants analyzed

Appendix H Figure 5 Sensitivity and Specificity of the Single-Item Test at the Optimal Cutoff to Detect Those Who Exceeded Various Drinking Limits Among Adolescents and Adults

This figure shows the sensitivity and specificity of the single-item test at the optimal cutoff to detect those who exceeded various drinking limits among adolescents and adults.

Abbreviations: CI = confidence interval; n = number of participants

Appendix H Figure 6 Sensitivity and Specificity of the AUDIT-C at the Optimal Cutoff to Detect Those Who Exceeded Various Drinking Limits Among Adults and Older Adults

This figure shows the sensitivity and specificity of the AUDIT-C at the optimal cutoff to detect those who exceeded various drinking limits among adults and older adults.

Abbreviations: AUDIT-C = Alcohol Use Disorders Identification Test, Consumption; CI = confidence interval; n = number of participants analyzed

Appendix H Figure 7 Sensitivity and Specificity of the AUDIT at the Optimal Cutoff to Detect Those Who Exceeded Various Drinking Limits Among Adolescents, Adults, and Older Adults

This figure shows the sensitivity and specificity of the AUDIT at the optimal cutoff to detect those who exceeded various drinking limits among adolescents, adults, and older adults.

Abbreviations: AUDIT = Alcohol Use Disorders Identification Test; CI = confidence interval; n = number of participants analyzed