# Appendix G Test Accuracy for Alcohol Dependence

## Adolescents

### Alcohol Dependence

#### Single-Item

Two studies assessed the accuracy of single-item screeners for alcohol dependence for a variety of age- and sex-specific cutoffs (Table 3). Frequency of alcohol use was used in two studies, with sensitivity ranging from 0.81 to 1.00 and specificity ranging from 0.71 to 0.97. A frequency of heavy episodic drinking screener (number of days they had 5 or more drinks per occasion in the past year) was used in one study to screen for dependence for a variety of age and sex groups, reporting sensitivity ranging from 0.42 to 0.83 and specificity ranging from 0.75 to 0.99. The lower sensitivity corresponded with younger age groups (males age 12—13 years, females age 12—15 years). One study^101^ used typical quantity of alcohol (drinks per drinking day) to screen for dependence among various age and sex groups, reporting sensitivity ranging from 0.68 to 1.00 and specificity ranging from 0.68 to 0.94. Sensitivity was higher for the younger age groups (sensitivity of 1.0 for males and females age 12—14 years).

#### AUDIT-C

No studies focused on adolescents used the AUDIT-C to screen for alcohol dependence.

#### AUDIT

One study^119^ reported accuracy at a cutoff of ≥8, finding a sensitivity of 0.75 (95% CI, 0.46 to 1.0) and specificity of 0.94 (95% CI, 0.92 to 0.96) (Table 3). Optimal cutoffs were lower (≥3^119^ and ≥7^131^) for two studies (sensitivity 1.00 [95% CI, 0.73 to 1.00] and 0.64 [95% CI, 0.32 to 0.88]; specificity 0.73 [95% CI, 0.70 to 0.77] and 0.75 [95% CI, 0.56 to 0.88], respectively). One study^119^ conducted with a U.S. primary care sample also reported the accuracy of the AUDIT at a cutoff of ≥5, with sensitivity of 0.83 (95% CI, 0.57 to 1.0) and specificity of 0.85 (95% CI, 0.82 to 0.88) (Table 3).

#### ASSIST

No studies focused on adolescents used the ASSIST to screen for alcohol dependence.

## Young Adults

### Alcohol Dependence

#### Single-Item

No studies focused on young adults used a single-item test to screen for alcohol dependence.

#### AUDIT-C

One study^127^ assessed the accuracy of the AUDIT-C to screen for alcohol dependence (Table 7). Black and white females had high sensitivity (1.0 and 0.99, respectively, 95% CI, NR for this study) but low specificity (0.57 and 0.23, respectively) at a cutoff of ≥3. Similarly, at a cutoff of ≥4, black and white males had high sensitivity (0.84 and 0.97) and low specificity (0.51 and 0.25). The optimal cutoffs for four sex and race subgroups ranged from ≥4 to ≥8 (sensitivity 0.81 to 1.00; specificity 0.62 to 0.76).

#### AUDIT

Two studies^95,^ ^127^ reported the accuracy of the AUDIT to screen for DSM-IV dependence (Table 7). Only one reported the accuracy for a cutoff of ≥8, with a sensitivity of 0.93 (95% CI, 0.88, 0.96) and specificity of 0.60 (95% CI, 0.57, 0.62).^127^ This study examined sex and race differences, so the optimal cutoff ranged from ≥7 to ≥13 for various race/sex groups. At the optimal cutoffs in two studies, sensitivity ranged from 0.75 to 0.86 and specificity ranged from 0.77 to 0.92.

#### ASSIST

No studies focused on young adults used the ASSIST to screen for alcohol dependence.

## General Adults

### Alcohol Dependence

#### Single-Item

Four studies^96,^ ^106,^ ^125,^ ^133^ assessed the accuracy of single-item screening tests to identify alcohol dependence (Table 11). Three studies used a 5/4+ drinks screening test with sensitivity ranging from 0.88 to 0.92 and specificity ranging from 0.82 to 0.84 at the optimal cutoffs, excluding subgroup analyses. One study^125^ among HIV patients and matched controls in the VA used a 6+ drinks screening test with sensitivity of 0.50 (95% CI, 0.38 to 0.62) and specificity of 0.91 (95% CI, 0.89 to 0.93) at the optimal cutoff; sensitivity was low in both the HIV+ patients (0.46 [95% CI, 0.32 to 0.63]) and the controls (0.52 [95% CI, 0.36 to 0.70]) in this study.

#### AUDIT-C

Six studies^106,^ ^107,^ ^125,^ ^129,^ ^132,^ ^133^ examined the accuracy of the AUDIT-C to screen for alcohol dependence (Table 11). At a cutoff of ≥3 in five studies,^106,^ ^107,^ ^125,^ ^129,^ ^133^ sensitivity ranged from 0.74 to 1.00 and specificity ranged from 0.40 to 0.73. Three of the four studies reported sensitivity of 0.95 or higher; the fourth was the study that recruited HIV patients and matched controls from the VA (sensitivity 0.74 [95% CI, 0.62, 0.83]).^125^ At a cutoff of ≥4 in three studies,^106,^ ^107,^ ^129^ sensitivity ranged from 0.88 to 0.96 and specificity ranged from 0.62 to 0.80 outside of VA settings, but again sensitivity was lower in VA patients; the study with VA HIV patients and matched controls had sensitivity of 0.69 (95% CI, 0.57, 0.79) and corresponding specificity of 0.82 (95% CI, 0.79 to 0.84).^125^ The optimal cutoffs ranged from ≥3 to ≥5. At the optimal cutoffs for five studies,^106,^ ^107,^ ^129,^ ^132,^ ^133^ sensitivity ranged from 0.80 to 0.96 and specificity ranged from 0.65 to 0.87. The study in VA HIV patients and matched controls had lower sensitivity at 0.74 (95% CI, 0.62 to 0.83) and specificity of 0.73 (95% CI, to 0.70 to 0.76) at their optimal cutoff of ≥3.^125^

#### AUDIT

Five studies reported the accuracy of the AUDIT at a cutoff of ≥8 (Table 12). Three of these studies reported sensitivity ranging from 0.74 to 0.80 and specificity ranging from 0.85 to 0.94. Two studies, one reporting accuracy for a female subgroup only^132^ and another recruiting HIV patients and matched controls from the VA,^125^ reported lower sensitivity at 0.39 (95% CI, 0.25 to 0.56) to 0.56 (95% CI, 0.44 to 0.68), respectively, and corresponding specificity of 0.96 (95% CI, 0.94 to 0.98) and 0.92 (95% CI, 0.89 to 0.93). There was a wide range in optimal cutoffs (≥4 to ≥13). At the optimal cutoffs, sensitivity ranged from 0.67 to 0.96 and specificity ranged from 0.70 to 0.98.

#### ASSIST

No studies focused on general adults used the ASSIST to screen for alcohol dependence.

## Older Adults

### Alcohol Dependence

#### ASSIST

No studies focused on older adults used a single-item screening test to screen for alcohol dependence.

#### AUDIT-C

One study reported accuracy among adults age 65 years or older who had drunk alcohol in the past year. At the optimal cutoff of ≥4, sensitivity was 0.88 (95% C, 0.67 to 0.95) and specificity was 0.73 (95% C, 0.71 to 0.74) (Table 15).

#### ASSIST

No studies focused on older adults used the ASSIST to screen for unhealthy alcohol use.

#### ASSIST

No studies focused on older adults used the ASSIST to screen for alcohol dependence.

#### CARET

No studies focused on older adults used the ASSIST to screen for alcohol dependence.

## Pregnant Women

### Alcohol Dependence

#### Single-Item

No studies focused on pregnant women used a single-item screening test to screen for alcohol dependence.

#### AUDIT-C

The study^106^ in a community sample of past-year alcohol users reported the accuracy of the AUDIT-C to screen for dependence in pregnant women who drank alcohol in the past year. At a cutoff of ≥3, sensitivity was 1.0 (95% CI, 0.70 to 1.00) and specificity was 0.70 (95% CI, 0.64 to 0.76). At the optimal cutoff of ≥4, sensitivity was 0.98 (95% CI, 0.70 to 1.00) and specificity was 0.86 (95% CI, 0.81 to 0.90) (Table 18).

#### Other Tools

No studies focused on pregnant women used the AUDIT, ASSIST, TWEAK, or T-ACE to screen for alcohol dependence.