# Appendix F Excluded Studies

Reason for Exclusion^*^
E1 | Study Aim: Not applicable/relevant to key question
E2a | Setting: Not in very high human development index country^*^
E2b | Setting: Screening and/or intervention is not conducted in, recruited from, or feasible for primary care
E2c | Setting: Conducted in emergency department or urgent care setting
E3a | Population:; - For screening, participants selected on the basis of alcohol or drug use or a related behavior or condition; - For interventions: Not among a screen-detected population (i.e., <50% of enrolled sample is recruited via population-based screening) or among those with addiction or dependence
E3b | Population: Otherwise out-of-scope (e.g., psychotic disorder, persons on chronic opioid therapy, court-mandated, incarcerated)
E3c | Population: Children <12 years
E4 | Outcome: No measure of alcohol use (only a composite substance use index) or no measure related to sensitivity and specificity for screening accuracy
E5a | Screening tool (KQ1, 2, 3): Assessment for drug or alcohol use does NOT include a brief standardized instrument or set of questions that is conducted in person or via telephone, mail, or electronically
E5b | Screening tool accuracy (KQ2): Not an included instrument (NIAAA one- or two-item screener or comparable, BSTAD, AUDIT and AUDIT-C, ASSIST, CARET, TWEAK, and T-ACE).
E5c | Intervention: Not an included intervention (e.g., medication, only contingency management, vocational rehabilitation, financial incentive)
E5e | Intervention: Prevention
E6 | Comparator: Not an included comparator (e.g., screening results given to control providers [KQ1, 3], no reference standard [KQ2], active intervention [KQ4, 5])
E8 | Followup: KQ1, 4: Less than 6 months post-baseline (except among pregnant women)
E9 | Study design: KQ1, 3, 4, 5=RCTs and CCTs, KQ2=screening accuracy, KQ5=large cohort or case control studies for medication trials
E10 | Study Quality: Poor

* Assigned at full-text phase.

1 Aalborg A, Miller B, Husson G, . Implementation of adolescent family-based substance use prevention programmes in health care settings: Comparisons across conditions and programmes. Health education journal. 2012;71(1):53–61. PMID: 22984294. KQ4E5e, KQ5E5e.22984294
2 Abar C, Hernandez L, Rodriquez A, . Trajectories of adolescent monthly alcohol use after receiving a brief intervention. Alcohol Clin Exp Res. 2014;38:290a. KQ4E3a, KQ5E3a.
3 Abar CC, Hernandez L, Rodriguez AM, . Trajectories of Adolescent Alcohol Use in the Year Following a Brief Alcohol Intervention. Journal of Studies on Alcohol & Drugs. 2015;76(5):710–20. PMID: 26402351. KQ4E3a, KQ5E3a.26402351
4 Abrams TE. Capsule commentary on McNeely et al., Validation of self-administered single item screening questions (SISQs) for unhealthy alcohol and drug use in primary care patients. J Gen Intern Med. 2015;30(12):1845. KQ2E9.26307385
5 Adams WL, Barry KL, Fleming MF. Screening for problem drinking in older primary care patients. JAMA. 1996;276(24):1964–7. PMID: 8971065. KQ2E5b.8971065
6 Adamson SJ, Sellman JD. Five-year outcomes of alcohol-dependent persons treated with motivational enhancement. J Stud Alcohol Drugs. 2008;69(4):589–93. KQ4E3a, KQ5E3a.18612575
7 Agabio R, Marras P, Gessa G, . Alcohol use disorders, and at-risk drinking in patients affected by a mood disorder, in Cagliari, Italy: sensitivity and specificity of different questionnaires. Alcohol Alcohol. 2007;42(6):575–81. KQ2E2b.17766313
8 Agostinelli G, Brown JM, Miller WR. Effects of normative feedback on consumption among heavy drinking college students. J Drug Educ. 1995;25(1):31–40. KQ4E8, KQ5E8.7776148
9 Aithal GP, Thornes H, Dwarakanath AD, . Measurement of carbohydrate-deficient transferrin (CDT) in a general medical clinic: is this test useful in assessing alcohol consumption. Alcohol Alcohol. 1998;33(3):304–9. PMID: 9632056. KQ2E6.9632056
10 Alden LE. Behavioral self-management controlled-drinking strategies in a context of secondary prevention. J Consult Clin Psychol. 1988;56(2):280–6. KQ4E3a, KQ5E3a.3372836
11 Alexander TL. Substance abuse screening with deaf clients: Development of a culturally sensitive scale. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2005;66(2-A):756. KQ2E4.
12 Ali R, Meena S, Eastwood B, . Ultra-rapid screening for substance-use disorders: the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST-Lite). Drug Alcohol Depend. 2013;132(1–2):352–61. PMID: 23561823. KQ4E5e, KQ5E5e.23561823
13 Altieri KM. Validating the Alcohol and Drug Use Survey and determining the relationships of familial and age-related variables with substance abuse of adolescents in a correctional facility. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2002;63(2-A):506. KQ2E2b.
14 Anderson P, Coulton S, Kaner E, . Delivery of Brief Interventions for Heavy Drinking in Primary Care: Outcomes of the ODHIN 5-Country Cluster Randomized Trial. Annals of Family Medicine. 2017;15(4):335–40. PMID: 28694269. KQ4E4, KQ5E4.28694269
15 Anderson P, Gual A, Spak F, . Implementing brief interventions for heavy drinking in primary health care-ODHIN baseline and preliminary outcome results. Alcohol Alcohol. 2013;48:i58–i9. KQ4E4, KQ5E4.
16 Anderson P, Gual A, Spak F, . Design of the ODHIN five country study-implementing brief interventions for heavy drinking in primary health care. Alcohol Alcohol. 2013;48:i58. KQ4E4, KQ5E4.
17 Andersson A, Wirehn AB, Olvander C, . Alcohol use among university students in Sweden measured by an electronic screening instrument. BMC Public Health. 2009;9:229. PMID: 19594906. KQ4E10, KQ5E10.19594906
18 Armitage CJ, Rowe R, Arden MA, . A brief psychological intervention that reduces adolescent alcohol consumption. J Consult Clin Psychol. 2014;82(3):546–50. PMID: 24491079. KQ4E8, KQ5E8.24491079
19 Armstrong M, LaPlante A, Allerton T, . An adapted holistic intervention to decrease alcohol consumption among people living with HIV/AIDS (PLWHA); a pilot study. Alcohol Clin Exp Res. 2015;39:21a. KQ4E9, KQ5E9.25623402
20 Armstrong MA, Kaskutas LA, Witbrodt J, . Using drink size to talk about drinking during pregnancy: a randomized clinical trial of Early Start Plus. Social work in health care. 2009;48(1):90–103. KQ4E10, KQ5E10.19197768
21 Babor T, Grant M, (Eds). Project on identification and management of alcohol-related problems: Report on Phase II: A randomized clinical trial of brief interventions in primary health care. Geneva: World Health Organization, Programme on Substance Abuse; 1992. PMID: KQ4E10, KQ5E10.
22 Babor TF, Higgins-Biddle JC, Dauser D, . Brief interventions for at-risk drinking: patient outcomes and cost-effectiveness in managed care organizations. Alcohol Alcohol. 2006;41(6):624–31. KQ4E10, KQ5E10.17035245
23 Bahorik A, Leibowitz A, Sterling S, . The effect of reductions in hazardous drinking on depression and anxiety symptoms. Alcohol Clin Exp Res. 2016;40:47a. KQ4E9, KQ5E9.26727521
24 Bailey KA, Baker AL, Webster RA, . Pilot randomized controlled trial of a brief alcohol intervention group for adolescents. Drug Alcohol Rev. 2004;23(2):157–66. PMID: 15370021. KQ4E3a, KQ5E3a.15370021
25 Baker AL, Kavanagh DJ, Kay-Lambkin FJ, . Randomized controlled trial of MICBT for co-existing alcohol misuse and depression: outcomes to 36-months. J Subst Abuse Treat. 2014;46(3):281–90. PMID: 24210534. KQ4E3a, KQ5E3a.24210534
26 Bannink R, Broeren S, Joosten-van Zwanenburg E, . Effectiveness of a Web-based tailored intervention (E-health4Uth) and consultation to promote adolescents’ health: randomized controlled trial. J Med Internet Res. 2014;16(5):e143. PMID: 24878521. KQ4E5e, KQ5E5e.24878521
27 Barry AE, Chaney BH, Stellefson ML, . Validating the ability of a single-item assessing drunkenness to detect hazardous drinking. American Journal of Drug & Alcohol Abuse. 2013;39(5):320–5. PMID: 23837735. KQ2E6.23837735
28 Barry KL, Fleming MF. Computerized administration of alcoholism screening tests in a primary care setting. J Am Board Fam Pract. 1990;3(2):93–8. PMID: 2185611. KQ2E5b.2185611
29 Barry KL, Fleming MF. The Alcohol Use Disorders Identification Test (AUDIT) and the SMAST-13: predictive validity in a rural primary care sample. Alcohol Alcohol. 1993;28(1):33–42. PMID: 8471085. KQ2E10.8471085
30 Bartels SJ, Coakley EH, Zubritsky C, . Improving access to geriatric mental health services: a randomized trial comparing treatment engagement with integrated versus enhanced referral care for depression, anxiety, and at-risk alcohol use. The American journal of psychiatry. 2004;161(8):1455–62. KQ2E9.15285973
31 Baumann S, Gaertner B, Haberecht K, . Who benefits from computer-based brief alcohol intervention? Day-to-day drinking patterns as a moderator of intervention efficacy. Drug Alcohol Depend. 2017;175:119–26. PMID: 28412302. KQ4E2b, KQ5E2b.28412302
32 Baumann S, Gaertner B, Schnuerer I, . The impact of a stage tailored intervention on alcohol use trajectories among those who do not intend to change. Drug Alcohol Depend. 2015;147:167–74. PMID: 25500129. KQ4E2b, KQ5E2b.25500129
33 Baumann S, Toft U, Aadahl M, . The long-term effect of a population-based life-style intervention on smoking and alcohol consumption. The Inter99 Study-a randomized controlled trial. Addiction. 2015;110(11):1853–60. PMID: 26173928. KQ4E5e, KQ5E5e.26173928
34 Bayles CJ. A randomized control study of a brief psychoeducational intervention on alcohol use with undergraduate students. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2016;77(6-B(E)): No Pagination Specified. KQ4E8, KQ5E8.
35 Bazzo S, Battistella G, Riscica P, . Reliability of a self-report Italian version of the AUDIT-C questionnaire, used to estimate alcohol consumption by pregnant women in an obstetric setting. Rivista di Psichiatria. 2015;50(2):89–94. KQ2E6.25994619
36 Beich A, Gannik D, Saelan H, . Screening and brief intervention targeting risky drinkers in Danish general practice-a pragmatic controlled trial. Alcohol Alcohol. 2007;42(6):593–603. KQ4E10, KQ5E10.17855332
37 Berks J, McCormick R. Screening for alcohol misuse in elderly primary care patients: a systematic literature review. International psychogeriatrics / IPA. 2008;20(6):1090–103. PMID: 18538045. KQ1E9, KQ3E9.18538045
38 Berman AH, Gajecki M, Fredriksson M, . Mobile Phone Apps for University Students With Hazardous Alcohol Use: Study Protocol for Two Consecutive Randomized Controlled Trials. JMIR Res Protoc. 2015;4(4):e139. PMID: 26693967. KQ4E3a, KQ5E3a.26693967
39 Berman AH, Wennberg P, Sinadinovic K. Changes in mental and physical well-being among problematic alcohol and drug users in 12-month Internet-based intervention trials. Psychol Addict Behav. 2015;29(1):97–105. PMID: 25664387. KQ4E3a, KQ5E3a.25664387
40 Berner MM, Kriston L, Bentele M, . The alcohol use disorders identification test for detecting at-risk drinking: a systematic review and meta-analysis. J Stud Alcohol Drugs. 2007;68(3):461–73. PMID: 17446987. KQ2E9.17446987
41 Bernhardt JM, Usdan S, Mays D, . Alcohol assessment among college students using wireless mobile technology. J Stud Alcohol Drugs. 2009;70(5):771–5. KQ2E5b.19737502
42 Bernstein J, Bernstein E, Hudson D, . Differences by gender at twelve months in a brief intervention trial among Mexican-origin young adults in the emergency department. Journal of ethnicity in substance abuse. 2016:1–18. PMID: 26821181. KQ4E2c, KQ5E2c.26766298
43 Bernstein M, Martin S, Wood M. A prospective test of impulsivity/sensation seeking and parental monitoring on alcohol involvement. Alcohol Clin Exp Res. 2013;37:37a. KQ4E9, KQ5E9.
44 Bertholet N, Cunningham JA, Faouzi M, . Internet-Based Brief Intervention to Prevent Unhealthy Alcohol Use among Young Men: A Randomized Controlled Trial. PLoS ONE. 2015;10(12):e0144146. PMID: 26642329. KQ4E5e, KQ5E5e.26642329
45 Bischof G, Grothues J, Reinhardt S, . Alcohol screening in general practices using the AUDIT: how many response categories are necessary? Eur Addict Res. 2007;13(1):25–30. PMID: 17172776. KQ2E4.17172776
46 Bischof G, Reinhardt S, Grothues J, . Effects of item sequence on the performance of the AUDIT in general practices. Drug Alcohol Depend. 2005;79(3):373–7. PMID: 16102379. KQ2E4.16102379
47 Blank ML, Connor J, Gray A, . Screening for hazardous alcohol use among university students using individual questions from the Alcohol Use Disorders Identification Test-Consumption. Drug & Alcohol Review. 2015;13:13. PMID: 25867022. KQ2E6.25867022
48 Blankers M, Koeter M, Schippers GM. Evaluating real-time internet therapy and online self-help for problematic alcohol consumers: a three-arm RCT protocol. BMC Public Health. 2009;9:16. PMID: 19144162. KQ4E3a, KQ5E3a.19144162
49 Blankers M, Koeter MW, Schippers GM. Internet therapy versus internet self-help versus no treatment for problematic alcohol use: A randomized controlled trial. J Consult Clin Psychol. 2011;79(3):330–41. PMID: 21534652. KQ4E3a, KQ5E3a.21534652
50 Blow F, Barry K, Chermack S, . Screening and brief intervention for at-risk drinking in older adults: Mental and physical health outcomes. Alcohol Clin Exp Res. 2012;36:24a. KQ4E9, KQ5E9.21797886
51 Boden MT, Kimerling R, Jacobs-Lentz J, . Seeking Safety treatment for male veterans with a substance use disorder and post-traumatic stress disorder symptomatology. Addiction. 2012;107(3):578–86. PMID: 21923756. KQ4E3a, KQ5E3a.21923756
52 Boekeloo BO, Jerry J, Lee-Ougo WI, . Randomized trial of brief office-based interventions to reduce adolescent alcohol use. Arch Pediatr Adolesc Med. 2004;158(7):635–42. KQ4E5e, KQ5E5e.15237062
53 Bonevski B, Campbell E, Sanson-Fisher RW. The validity and reliability of an interactive computer tobacco and alcohol use survey in general practice. Addict Behav. 2010;35(5):492–8. PMID: 20092954. KQ2E6.20092954
54 Bonevski B, Sanson-Fisher RW, Campbell E, . Randomized controlled trial of a computer strategy to increase general practitioner preventive care. Preventive medicine. 1999;29(6 Pt 1):478–86. PMID: 10600428. KQ4E8, KQ5E8.10600428
55 Boß L, Lehr D, Berking M, . Evaluating the (cost-)effectiveness of guided and unguided Internet-based self-help for problematic alcohol use in employees-a three arm randomized controlled trial. BMC Public Health. 2015;15:1043. KQ4E3a, KQ5E3a.26458872
56 Boudreaux ED, Abar B, Baumann BM, . A randomized clinical trial of the health evaluation and referral assistant (HERA): research methods. Contemp Clin Trials. 2013;35(2):87–96. PMID: 23665335. KQ4E2c, KQ5E2c.23665335
57 Braaten K, Briegleb C, Hauke S, . Screening pregnant young adults for alcohol and drug use: a pilot study. J Addict Med. 2008;2(2):74–8. PMID: 21768975. KQ1E9, KQ2E9, KQ3E9.21768975
58 Bradley K, Bobb J, Ludman E, . Does nurse care management of patients at high risk for alcohol use disorders improve drinking outcomes? Results of the choosing healthier drinking options in primary care (CHOICE) trial. Journal of general internal medicine Conference: 40th annual meeting of the society of general internal medicine, SGIM 2017 United states. 2017;32(2 Supplement 1):S169. KQ4E11, KQ5E11.
59 Bradley KA, Boyd-Wickizer J, Powell SH, . Alcohol screening questionnaires in women: a critical review. JAMA. 1998;280(2):166–71. PMID: 9669791. KQ2E9.9669791
60 Bradley KA, Bush KR, McDonell MB, . Screening for problem drinking: Comparison of CAGE and AUDIT. J Gen Intern Med. 1998;13(6):379–88. PMID: 17551799. KQ2E9.17551799
61 Bradley KA, Ludman EJ, Chavez LJ, . Patient-centered primary care for adults at high risk for AUDs: the Choosing Healthier Drinking Options In primary CarE (CHOICE) trial. Addict Sci Clin Pract. 2017;12(1):15. PMID: 28514963. KQ4E11, KQ5E11.28514963
62 Bradley KA, McDonell MB, Bush K, . The AUDIT alcohol consumption questions: reliability, validity, and responsiveness to change in older male primary care patients. Alcohol Clin Exp Res. 1998;22(8):1842–9. PMID: 9835306. KQ2E9.9835306
63 Brendryen H, Johansen A, Duckert F, . A Pilot Randomized Controlled Trial of an Internet-Based Alcohol Intervention in a Workplace Setting. Int J Behav Med. 2017. PMID: 28755326. KQ4E2b, KQ5E2b.28755326
64 Brief D, Rubin A, Enggasser J, . Web-based intervention for returning veterans with risky alcohol use. Journal of contemporary psychotherapy. 2012;41(4):237–46. KQ4E3a, KQ5E3a.
65 Brief DJ, Rubin A, Keane TM, . Web intervention for OEF/OIF veterans with problem drinking and PTSD symptoms: a randomized clinical trial. Journal of Consulting & Clinical Psychology. 2013;81(5):890–900. PMID: 23875821. KQ4E3a, KQ5E3a.23875821
66 Broadhead WE, Leon AC, Weissman MM, . Development and validation of the SDDS-PC screen for multiple mental disorders in primary care. Archives of family medicine. 1995;4(3):211–9. PMID: 7881602. KQ2E5b.7881602
67 Broning S, Sack PM, Thomsen M, . Implementing and evaluating the German adaptation of the “Strengthening Families Program 10 - 14”- a randomized-controlled multicentre study. BMC Public Health. 2014;14:83. PMID: 24467917. KQ4E5e, KQ5E5e.24467917
68 Broyles LM, Wieland ME, Confer AL, . Alcohol brief intervention for hospitalized veterans with hazardous drinking: protocol for a 3-arm randomized controlled efficacy trial. Addict Sci Clin Pract. 2015;10:13. PMID: 25968121. KQ4E2b, KQ5E2b.25968121
69 Burns E, Gray R, Smith LA. Brief screening questionnaires to identify problem drinking during pregnancy: a systematic review. Addiction. 2010;105(4):601–14. PMID: 20403013. KQ2E9.20403013
70 Burton LC, Paglia MJ, German PS, . The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. The Medicare Preventive Services Research Team. Preventive medicine. 1995;24(5):492–7. PMID: 8524724. KQ4E1, KQ5E1.8524724
71 Bush K, Kivlahan DR, McDonell MB, . The AUDIT alcohol consumption questions (AUDIT-C): an effective brief screening test for problem drinking. Ambulatory Care Quality Improvement Project (ACQUIP). Alcohol Use Disorders Identification Test. Arch Intern Med. 1998;158(16):1789–95. PMID: 9738608. KQ2E9.9738608
72 Calabria B, Clifford A, Shakeshaft AP, . Identifying Aboriginal-specific AUDIT-C and AUDIT-3 cutoff scores for at-risk, high-risk, and likely dependent drinkers using measures of agreement with the 10-item Alcohol Use Disorders Identification Test. Addict Sci Clin Pract. 2014;9:17. PMID: 25179547. KQ2E6.25179547
73 Cameron D, Epton T, Norman P, . A theory-based online health behaviour intervention for new university students (U@Uni:LifeGuide): results from a repeat randomized controlled trial. Trials. 2015;16:555. PMID: 26643917. KQ4E10, KQ5E10.26643917
74 Canagasaby A, Vinson DC. Screening for hazardous or harmful drinking using one or two quantity-frequency questions. Alcohol & Alcoholism. 2005;40(3):208–13. PMID: 15797883. KQ2E2c.15797883
75 Ceperich SD, Ingersoll KS. Motivational interviewing + feedback intervention to reduce alcohol-exposed pregnancy risk among college binge drinkers: determinants and patterns of response. J Behav Med. 2011;34(5):381–95. PMID: 21318412. KQ4E4, KQ5E4.21318412
76 Chambers JE, Brooks AC, Medvin R, . Examining multi-session brief intervention for substance use in primary care: research methods of a randomized controlled trial. Addict Sci Clin Pract. 2016;11(1):8. PMID: 27090097. KQ4E4, KQ5E4.27090097
77 Chaney BH, Barry AE, Cremeens-Matthews J, . Psychometric properties of a single-item assessing drunkenness to identify hazardous drinking: A replication study. Journal of Substance Use. 2016;21(2):153–7. KQ2E5b.
78 Chang G, Fisher ND, Hornstein MD, . Identification of risk drinking women: T-ACE screening tool or the medical record. J Womens Health (Larchmt). 2010;19(10):1933–9. PMID: 20839966. KQ2E9.20839966
79 Chang G, Goetz MA, Wilkins-Haug L, . Identifying prenatal alcohol use: screening instruments versus clinical predictors. Am J Addict. 1999;8(2):87–93. PMID: 10365188. KQ2E9.10365188
80 Chang G, Wilkins-Haug L, Berman S, . The TWEAK: application in a prenatal setting. J Stud Alcohol Drugs. 1999;60(3):306–9. PMID: 10371256. KQ2E9.10371256
81 Chang G, Wilkins-Haug L, Berman S, . Alcohol use and pregnancy: improving identification. Obstetrics & Gynecology. 1998;91(6):892–8. PMID: 9610992. KQ2E9.9610992
82 Chang JW, Kim JS, Jung JG, . Validity of Alcohol Use Disorder Identification Test-Korean Revised Version for Screening Alcohol Use Disorder according to Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition Criteria. Korean J Fam Med. 2016;37(6):323–8. PMID: 27900069. KQ2E10.27900069
83 Cherpitel CJ. Performance of screening instruments for identifying alcohol dependence in the general population, compared with clinical populations. Alcohol Clin Exp Res. 1998;22(7):1399–404. PMID: 9802519. KQ2E5b.9802519
84 Cherpitel CJ. Differences in performance of screening instruments for problem drinking among blacks, whites and Hispanics in an emergency room population. J Stud Alcohol Drugs. 1998;59(4):420–6. PMID: 9647424. KQ2E2c.9647424
85 Cherpitel CJ. Screening for alcohol problems in the U.S. general population: a comparison of the CAGE and TWEAK by gender, ethnicity, and services utilization. J Stud Alcohol Drugs. 1999;60(5):705–11. PMID: 10487741. KQ2E5b.10487741
86 Cherpitel CJ, Ye Y, Moskalewicz J, . Does Brief Intervention Work For Heavy Episodic Drinking? A Comparison of Emergency Department Patients in Two Cultures. Alkoholizm i narkomania. 2015;28(3):145–62. PMID: 26688611. KQ4E2c, KQ5E2c.26688611
87 Cherry AL, Dillon ME. The AC-OK Cooccurring Screen: Reliability, Convergent Validity, Sensitivity, and Specificity. J Addict. 2013;2013:573906. PMID: 24826362. KQ4E3a, KQ5E3a.24826362
88 Chi FW, Weisner CM, Mertens JR, . Alcohol brief intervention in primary care: Blood pressure outcomes in hypertensive patients. J Subst Abuse Treat. 2017;77:45–51. PMID: 28476271. KQ4E6, KQ5E6.28476271
89 Chiauzzi E, Green TC, Lord S, . My student body: a high-risk drinking prevention web site for college students. J Am Coll Health. 2005;53(6):263–74. PMID: 15900990. KQ4E3a, KQ5E3a.15900990
90 Chiodo LM, Sokol RJ, Delaney-Black V, . Validity of the T-ACE in pregnancy in predicting child outcome and risk drinking. Alcohol. 2010;44(7–8):595–603. PMID: 20053522. KQ2E9.20053522
91 Cisler RA, Barrett D, Zweben A, . Integrating a Brief Motivational Treatment for Problem Drinkers in a Private Outpatient Clinic: Client Characteristics, Utilization of Services and Preliminary Outcomes. Alcoholism Treatment Quarterly. 2003;21(3):1–21. KQ4E9, KQ5E9.
92 Clark DB, Chung T, Martin C. Alcohol use frequency as a screen for alcohol use disorders in adolescents. International Journal of Adolescent Medicine & Health. 2006;18(1):181–7. PMID: 16639872. KQ2E10.16639872
93 Clements R. Psychometric properties of the Substance Abuse Subtle Screening Inventory-3. J Subst Abuse Treat. 2002;23(4):419–23. PMID: 12495805. KQ2E5b.12495805
94 Cleveland MJ, Hultgren B, Varvil-Weld L, . Moderation of a parent-based intervention on transitions in drinking: Examining the role of normative perceptions and attitudes among high- and low-risk first-year college students. Alcohol Clin Exp Res. 2013;37(9):1587–94. KQ4E8, KQ5E8.23551037
95 Clinton-Sherrod M, Morgan-Lopez AA, Brown JM, . Incapacitated sexual violence involving alcohol among college women: the impact of a brief drinking intervention. Violence Against Women. 2011;17(1):135–54. PMID: 21199812. KQ4E8, KQ5E8.21199812
96 Collins SE, Carey KB, Sliwinski MJ. Mailed personalized normative feedback as a brief intervention for at-risk college drinkers. J Stud Alcohol. 2002;63(5):559–67. PMID: 12380852. KQ4E10, KQ5E10.12380852
97 Cordoba R, Delgado MT, Pico V, . Effectiveness of brief intervention on non-dependent alcohol drinkers (EBIAL): a Spanish multi-centre study. Family practice. 1998;15(6):562–8. PMID: 10078798. KQ4E10, KQ5E10.10078798
98 Cornelius JR, Douaihy A, Bukstein OG, . Evaluation of cognitive behavioral therapy/motivational enhancement therapy (CBT/MET) in a treatment trial of comorbid MDD/AUD adolescents. Addict Behav. 2011;36(8):843–8. KQ4E3a, KQ5E3a.21530092
99 Correa-Fernandez V, Diaz-Toro EC, Reitzel LR, . Combined treatment for at-risk drinking and smoking cessation among Puerto Ricans: A randomized clinical trial. Addict Behav. 2017;65:185–92. PMID: 27825036. KQ4E3b, KQ5E3b.27825036
100 Cortes Tomas MT, Gimenez Costa JA, Motos-Selles P, . The utility of the Alcohol Use Disorders Identification Test (AUDIT)for the analysis of binge drinking in university students. Psicothema. 2017;29(2):229–35. PMID: 28438247. KQ2E6.28438247
101 Cortes-Tomas MT, Gimenez-Costa JA, Motos-Selles P, . Revision of AUDIT Consumption Items to Improve the Screening of Youth Binge Drinking. Front Psychol. 2017;8:910. PMID: 28642722. KQ2E6.28642722
102 Crombie IK, Irvine L, Williams B, . A mobile phone intervention to reduce binge drinking among disadvantaged men: study protocol for a randomised controlled cost-effectiveness trial. Trials. 2014;15:494. PMID: 25526870. KQ4E4, KQ5E4.25526870
103 Cucciare MA, Weingardt KR, Ghaus S, . A randomized controlled trial of a web-delivered brief alcohol intervention in Veterans Affairs primary care. J Stud Alcohol Drugs. 2013;74(3):428–36. PMID: 23490572. KQ4E3a, KQ5E3a.23490572
104 Cunningham JA. Comparison of two internet-based interventions for problem drinkers: randomized controlled trial. J Med Internet Res. 2012;14(4):e107. PMID: 22954459. KQ4E3a, KQ5E3a.22954459
105 Cunningham JA, Hendershot CS, Rehm J. Randomized controlled trial of a minimal versus extended Internet-based intervention for problem drinkers: study protocol. BMC Public Health. 2015;15:21. PMID: 25604206. KQ4E3a, KQ5E3a.25604206
106 Cunningham JA, Shorter GW, Murphy M, . Randomized Controlled Trial of a Brief Versus Extended Internet Intervention for Problem Drinkers. Int J Behav Med. 2016. PMID: 27770293. KQ4E3a, KQ5E3a.27770293
107 Cyr MG, Wartman SA. The effectiveness of routine screening questions in the detection of alcoholism. JAMA. 1988;259(1):51–4. PMID: 3334771. KQ2E6.3334771
108 Dagmar MH, Anne M, Daniele L, . Prism-Ado: Cluster Randomised Trial of a Brief Primary Care Intervention Addressing Excessive Substance Use in Young People. Turkish Archives of Pediatrics. 2013;48:34. KQ4E2a, KQ5E2a.
109 Dawson DA, Grant BF, Stinson FS. The AUDIT-C: screening for alcohol use disorders and risk drinking in the presence of other psychiatric disorders. Compr Psychiatry. 2005;46(6):405–16. PMID: 16275207. KQ2E10.16275207
110 De Silva P, Jayawardana P, Pathmeswaran A. Concurrent validity of the alcohol use disorders identification test (AUDIT). Alcohol & Alcoholism. 2008;43(1):49–50. PMID: 17855334. KQ2E2a.17855334
111 de Torres LA, Rebollo EM, Ruiz-Moral R, . Diagnostic usefulness of the Alcohol Use Disorders Identification Test (AUDIT) questionnaire for the detection of hazardous drinking and dependence on alcohol among Spanish patients. Eur J Gen Pract. 2009;15(1):15–21. PMID: 19418376. KQ2E2b.19418376
112 Deady M, Mills KL, Teesson M, . An Online Intervention for Co-Occurring Depression and Problematic Alcohol Use in Young People: Primary Outcomes From a Randomized Controlled Trial. J Med Internet Res. 2016;18(3):e71. PMID: 27009465. KQ4E3a, KQ5E3a.27009465
113 Deady M, Teesson M, Kay-Lambkin F, . Evaluating a brief, internet-based intervention for co-occurring depression and problematic alcohol use in young people: protocol for a randomized controlled trial. JMIR Res Protoc. 2014;3(1):e6. PMID: 24583824. KQ4E3a, KQ5E3a.24583824
114 Dermen KH, Thomas SN. Randomized controlled trial of brief interventions to reduce college students’ drinking and risky sex. Psychol Addict Behav. 2011;25(4):583–94. PMID: 21928866. KQ4E3a, KQ5E3a.21928866
115 Dewost AV, Michaud P, Arfaoui S, . Fast alcohol consumption evaluation: a screening instrument adapted for French general practitioners. Alcoholism: Clinical & Experimental Research. 2006;30(11):1889–95. PMID: 17067354. KQ2E5b.17067354
116 Dieperink E, Fuller B, Isenhart C, . Efficacy of motivational enhancement therapy on alcohol use disorders in patients with chronic hepatitis C: A randomized controlled trial. Addiction. 2014;109(11):1869–77. KQ4E3a, KQ5E3a.25040898
117 Dolman JM, Hawkes ND. Combining the audit questionnaire and biochemical markers to assess alcohol use and risk of alcohol withdrawal in medical inpatients. Alcohol & Alcoholism. 2005;40(6):515–9. PMID: 16103035. KQ2E3b.16103035
118 D’Onofrio G, Fiellin DA, Pantalon MV, . A brief intervention reduces hazardous and harmful drinking in emergency department patients. Ann Emerg Med. 2012;60(2):181–92. PMID: 22459448. KQ4E2c, KQ5E2c.22459448
119 Donovan DM, Kivlahan DR, Doyle SR, . Concurrent validity of the Alcohol Use Disorders Identification Test (AUDIT) and AUDIT zones in defining levels of severity among out-patients with alcohol dependence in the COMBINE study. Addiction. 2006;101(12):1696–704. PMID: 17156168. KQ2E3a.17156168
120 Donovan E, Das Mahapatra P, Green TC, . Efficacy of an online intervention to reduce alcohol-related risks among community college students. Addict Res Theory. 2015;23(5):437–47. KQ4E3a, KQ5E3a.
121 Doumas D, Andersen L. Reducing alcohol use in first-year university students: Evaluation of a web-based personalized feedback program. Journal of College Counseling. 2009;12(1):18–32. PMID: None. KQ4E8, KQ5E8.
122 Doumas DM, Esp S, Flay B, . A Randomized Controlled Trial Testing the Efficacy of a Brief Online Alcohol Intervention for High School Seniors. Journal of Studies on Alcohol & Drugs. 2017;78(5):706–15. PMID: 28930058. KQ4E8, KQ5E8.28930058
123 Doumas DM, Hausheer R, Esp S, . Reducing alcohol use among 9th grade students: 6 month outcomes of a brief, Web-based intervention. J Subst Abuse Treat. 2014;47(1):102–5. PMID: 24666810. KQ4E5e, KQ5E5e.24666810
124 Dum M, Sobell LC, Sobell MB, . A Quick Drinking Screen for identifying women at risk for an alcohol-exposed pregnancy. Addict Behav. 2009;34(9):714–6. PMID: 19406583. KQ2E3a.19406583
125 Durbeej N, Berman AH, Gumpert CH, . Validation of the Alcohol Use Disorders Identification Test and the Drug Use Disorders Identification Test in a Swedish sample of suspected offenders with signs of mental health problems: results from the Mental Disorder, Substance Abuse and Crime study. J Subst Abuse Treat. 2010;39(4):364–77. PMID: 20822878. KQ2E3b.20822878
126 Duru OK, Xu H, Moore AA, . Examining the Impact of Separate Components of a Multicomponent Intervention Designed to Reduce At-Risk Drinking Among Older Adults: The Project SHARE Study. Alcoholism: Clinical & Experimental Research. 2015;39(7):1227–35. PMID: 26033430. KQ4E4, KQ5E4.26033430
127 Dybek I, Bischof G, Grothues J, . The reliability and validity of the Alcohol Use Disorders Identification Test (AUDIT) in a German general practice population sample. J Stud Alcohol Drugs. 2006;67(3):473–81. PMID: 16608159. KQ2E9.16608159
128 Dyer P. Brief substance dependence screening for women. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2006;67(6-B):3447. KQ2E3a.
129 Ekman DS, Andersson A, Nilsen P, . Electronic screening and brief intervention for risky drinking in Swedish university students-a randomized controlled trial. Addict Behav. 2011;36(6):654–9. PMID: 21316157. KQ4E10, KQ5E10.21316157
130 Essex HN, White IR, Khadjesari Z, . Quality of life among hazardous and harmful drinkers: EQ-5D over a 1-year follow-up period. Qual Life Res. 2014;23(2):733–43. PMID: 24026632. KQ4E3a, KQ5E3a.24026632
131 Estrada Y, Rosen A, Huang S, . Efficacy of a Brief Intervention to Reduce Substance Use and Human Immunodeficiency Virus Infection Risk Among Latino Youth. J Adolesc Health. 2015. PMID: 26549551. KQ4E5e, KQ5E5e.26549551
132 Fang L, Schinke SP. Two-year outcomes of a randomized, family-based substance use prevention trial for Asian American adolescent girls. Psychol Addict Behav. 2013;27(3):788–98. PMID: 23276322. KQ4E5e, KQ5E5e.23276322
133 Fang L, Schinke SP, Cole KC. Preventing substance use among early Asian-American adolescent girls: initial evaluation of a web-based, mother-daughter program. J Adolesc Health. 2010;47(5):529–32. PMID: 20970090. KQ4E5e, KQ5E5e.20970090
134 Feinn R, Gelernter J, Cubells JF, . Sources of unreliability in the diagnosis of substance dependence. J Stud Alcohol Drugs. 2009;70(3):475–81. KQ2E5a.19371499
135 Feldman N, Chatton A, Khan R, . Alcohol-related brief intervention in patients treated for opiate or cocaine dependence: a randomized controlled study.[Erratum appears in Subst Abuse Treat Prev Policy. 2013;8:28]. Subst Abuse Treat Prev Policy. 2011;6:22. PMID: 21849027. KQ4E3b, KQ5E3b.21849027
136 Feldstein Ewing SW, LaChance HA, Bryan A, . Do genetic and individual risk factors moderate the efficacy of motivational enhancement therapy? Drinking outcomes with an emerging adult sample. Addict Biol. 2009;14(3):356–65. PMID: 19298319. KQ4E3a, KQ5E3a.19298319
137 Feldstein SW. Motivational interviewing with late-adolescent/college underage drinkers: An investigation of therapeutic alliance. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2008;68(7-B):4821. KQ4E8, KQ5E8.
138 Fernandez AC, Wood MD, Laforge R, . Randomized trials of alcohol-use interventions with college students and their parents: lessons from the Transitions Project. Clinical trials. 2011;8(2):205–13. KQ4E4, KQ5E4.21270141
139 Ferrer RL, Mody-Bailey P, Jaen CR, . A medical assistant-based program to promote healthy behaviors in primary care. Ann Fam Med. 2009;7(6):504–12. KQ4E4, KQ5E4.19901309
140 Field C, Walters S, Marti CN, . A multisite randomized controlled trial of brief intervention to reduce drinking in the trauma care setting: how brief is brief? Ann Surg. 2014;259(5):873–80. PMID: 24263324. KQ4E2c, KQ5E2c.24263324
141 Fiellin DA, Reid MC, O’Connor PG. Screening for alcohol problems in primary care: a systematic review. Arch Intern Med. 2000;160(13):1977–89. PMID: 10888972. KQ2E9.10888972
142 Fink A, Elliott MN, Tsai M, . An evaluation of an intervention to assist primary care physicians in screening and educating older patients who use alcohol. Journal of the American Geriatrics Society. 2005;53(11):1937–43. KQ4E5e, KQ5E5e.16274375
143 Fishburne JW, Brown JM. How do college students estimate their drinking? comparing consumption patterns among quantity-frequency, graduated frequency, and timeline follow-back methods. J Alcohol Drug Educ. 2006;50(1):15–33. KQ2E4.
144 Fleming MF, Barry KL. A three-sample test of a masked alcohol screening questionnaire. Alcohol Alcohol. 1991;26(1):81–91. PMID: 1854376. KQ2E6.1854376
145 Fleming MF, Barry KL. The effectiveness of alcoholism screening in an ambulatory care setting. J Stud Alcohol. 1991;52(1):33–6. PMID: 1994120. KQ2E5b.1994120
146 Floyd RL, Sobell M, Velasquez MM, . Preventing alcohol-exposed pregnancies: a randomized controlled trial. Am J Prev Med. 2007;32(1):1–10. PMID: 17218187. KQ4E3a, KQ5E3a.17218187
147 Fridberg D, King A. Integrating alcohol challenge feedback in a brief intervention for young adult heavy drinker-smokers: A pilot study. Alcohol Clin Exp Res. 2014;38:211a. KQ4E3a, KQ5E3a.
148 Friedmann PD, Saitz R, Gogineni A, . Validation of the screening strategy in the NIAAA “Physicians’ Guide to Helping Patients with Alcohol Problems”. J Stud Alcohol Drugs. 2001;62(2):234–8. PMID: 11332444. KQ2E2c.11332444
149 Fucito LM, DeMartini KS, Hanrahan TH, . Using Sleep Interventions to Engage and Treat Heavy-Drinking College Students: A Randomized Pilot Study. Alcoholism: Clinical & Experimental Research. 2017;41(4):798–809. PMID: 28118486. KQ4E3a, KQ5E3a.28118486
150 Gajecki M, Andersson C, Rosendahl I, . Skills Training via Smartphone App for University Students with Excessive Alcohol Consumption: a Randomized Controlled Trial. Int J Behav Med. 2017. PMID: 28224445. KQ4E8, KQ5E8.28224445
151 Gale TC, White JA, Welty TK. Differences in detection of alcohol use in a prenatal population (on a Northern Plains Indian Reservation) using various methods of ascertainment. S D J Med. 1998;51(7):235–40. PMID: 9676158. KQ2E6.9676158
152 Ganz T, Braun M, Laging M, . Effects of a stand-alone web-based electronic screening and brief intervention targeting alcohol use in university students of legal drinking age: A randomized controlled trial. Addict Behav. 2017;77:81–8. PMID: 28985586. KQ4E10, KQ5E10.28985586
153 Gaume J, Gmel G, Faouzi M, . Is brief motivational intervention effective in reducing alcohol use among young men voluntarily receiving it? A randomized controlled trial. Alcohol Clin Exp Res. 2011;35(10):1822–30. PMID: 21777259. KQ4E3a, KQ5E3a.21777259
154 Geisner IM, Neighbors C, Lee CM, . Evaluating personal alcohol feedback as a selective prevention for college students with depressed mood. Addict Behav. 2007;32(12):2776–87. KQ4E5e, KQ5E5e.17499445
155 Geneste J, Pereira B, Arnaud B, . CAGE, RAPS4, RAPS4-QF and AUDIT screening tests for men and women admitted for acute alcohol intoxication to an emergency department: are standard thresholds appropriate? Alcohol & Alcoholism. 2012;47(3):273–81. PMID: 22414922. KQ2E2c.22414922
156 Gerrard M, Gibbons FX, Brody GH, . A theory-based dual-focus alcohol intervention for preadolescents: the Strong African American Families Program. Psychol Addict Behav. 2006;20(2):185–95. KQ4E5e, KQ5E5e.16784365
157 Gillespie W, Holt JL, Blackwell RL. Measuring outcomes of alcohol, marijuana, and cocaine use among college students: A preliminary test of the Shortened Inventory of Problems-Alcohol and Drugs (SIP-AD). J Drug Issues. 2007;37(3):549–68. KQ2E4.
158 Gilmore A, Bountress K. Reducing drinking to cope among college women: Secondary outcomes of a web-based alcohol use and sexual assault risk reduction intervention. Alcohol Clin Exp Res. 2016;40:70a. KQ4E4, KQ5E4.
159 Gjestad R, Franck J, Lindberg S, . Early Treatment for Women with Alcohol Addiction (EWA) reduces mortality: a randomized controlled trial with long-term register follow-up. Alcohol Alcohol. 2011;46(2):170–6. PMID: 21273301. KQ4E2b, KQ5E2b.21273301
160 Gmel G, Venzin V, Marmet K, . A quasi-randomized group trial of a brief alcohol intervention on risky single occasion drinking among secondary school students. Int J Public Health. 2012;57(6):935–44. PMID: 23089675. KQ4E2b, KQ5E2b.23089675
161 Goransson M, Magnusson A, Heilig M. Identifying hazardous alcohol consumption during pregnancy: implementing a research-based model in real life. Acta obstetricia et gynecologica Scandinavica. 2006;85(6):657–62. KQ4E1, KQ5E1.16752255
162 Grant BF, Dawson DA, Stinson FS, . The Alcohol Use Disorder and Associated Disabilities Interview Schedule-IV (AUDADIS-IV): reliability of alcohol consumption, tobacco use, family history of depression and psychiatric diagnostic modules in a general population sample. Drug Alcohol Depend. 2003;71(1):7–16. PMID: 12821201. KQ2E5b.12821201
163 Gregory RJ, Remen AL, Soderberg M, . A controlled trial of psychodynamic psychotherapy for co-occurring borderline personality disorder and alcohol use disorder: six-month outcome. J Am Psychoanal Assoc. 2009;57(1):199–205. KQ4E3a, KQ5E3a.19270255
164 Group WAW. The Alcohol, Smoking and Substance Involvement Screening Test (ASSIST): development, reliability and feasibility. Addiction. 2002;97(9):1183–94. KQ2E4.12199834
165 Gryczynski J, Mitchell S, Peterson T, . The relationship between services delivered and substance use outcomes in New Mexico’s Screening, Brief Intervention, Referral and Treatment (SBIRT) Initiative. Drug Alcohol Depend. 2011;118(2–3):152–7. PMID: 21482039. KQ4E9, KQ5E9.21482039
166 Guillemont J, Cogordan C, Nalpas B, . Effectiveness of a web-based intervention to reduce alcohol consumption among French hazardous drinkers: a randomized controlled trial. Health Educ Res. 2017;32(4):332–42. PMID: 28854571. KQ4E8, KQ5E8.28854571
167 Hagman BT. Performance of the AUDIT in Detecting DSM-5 Alcohol Use Disorders in College Students. Subst Use Misuse. 2016;51(11):1521–8. PMID: 27438676. KQ2E3a.27438676
168 Haller D, Meynard A, Lefebvre D, . Prism-ado: Cluster randomised trial of a brief primary care intervention addressing excessive substance use in young people. Turk Pediatri Arsivi. 2013;48:34. KQ4E11, KQ5E11.
169 Haller DM, Meynard A, Lefebvre D, . Effectiveness of training family physicians to deliver a brief intervention to address excessive substance use among young patients: a cluster randomized controlled trial. CMAJ: Canadian Medical Association journal = journal de l’Association medicale canadienne. 2014;186(8):E263–72. PMID: 24616136. KQ1E5a, KQ3E5a.24616136
170 Hamilton FL, Hornby J, Sheringham J, . DIgital Alcohol Management ON Demand (DIAMOND) feasibility randomised controlled trial of a web-based intervention to reduce alcohol consumption in people with hazardous and harmful use versus a face-to-face intervention: protocol. Pilot & Feasibility Studies. 2015;1:28. PMID: 27965806. KQ4E3a, KQ5E3a.27965806
171 Harris MF, Chan BC, Laws RA, . The impact of a brief lifestyle intervention delivered by generalist community nurses (CN SNAP trial). BMC Public Health. 2013;13:375. PMID: 23607755. KQ4E5e, KQ5E5e.23607755
172 Harris SK, Csemy L, Sherritt L, . Computer-facilitated substance use screening and brief advice for teens in primary care: an international trial. Pediatrics. 2012;129(6):1072–82. PMID: 22566420. KQ4E5e, KQ5E5e.22566420
173 Harrison PA, Godecker A, Sidebottom AC. Validation of the alcohol use module from a multidimensional prenatal psychosocial risk screening instrument. Maternal & Child Health Journal. 2012;16(9):1791–800. PMID: 22120427. KQ2E5b.22120427
174 Haug S, Castro RP, Filler A, . Efficacy of an Internet and SMS-based integrated smoking cessation and alcohol intervention for smoking cessation in young people: study protocol of a two-arm cluster randomised controlled trial. BMC Public Health. 2014;14:1140. PMID: 25369857. KQ4E5e, KQ5E5e.25369857
175 Havard A, Shakeshaft AP, Conigrave KM. Randomized Controlled Trial of Mailed Personalized Feedback for Risky Drinkers in the Emergency Department: The Impact on Alcohol Consumption, Alcohol-Related Injuries, and Repeat Emergency Department Presentations. Alcoholism: Clinical & Experimental Research. 2015;39(7):1260–6. PMID: 26031313. KQ4E2c, KQ5E2c.26031313
176 Helmer SM, Muellmann S, Zeeb H, . Development and evaluation of the efficacy of a web-based ‘social norms’-intervention for the prevention and reduction of substance use in a cluster-controlled trial conducted at eight German universities. BMC Public Health. 2016;16:252. PMID: 26969585. KQ4E3a, KQ5E3a.26969585
177 Helzer JE, Rose GL, Badger GJ, . Using interactive voice response to enhance brief alcohol intervention in primary care settings. J Stud Alcohol Drugs. 2008;69(2):251–8. KQ4E3a, KQ5E3a.18299766
178 Hester RK, Delaney HD, Campbell W. ModerateDrinking.Com and moderation management: outcomes of a randomized clinical trial with non-dependent problem drinkers. Journal of Consulting & Clinical Psychology. 2011;79(2):215–24. PMID: 21319896. KQ4E3a, KQ5E3a.21319896
179 Hides L, Carroll S, Scott R, . Quik Fix: a randomized controlled trial of an enhanced brief motivational interviewing intervention for alcohol/cannabis and psychological distress in young people. Psychother Psychosom. 2013;82(2):122–4. PMID: 23295899. KQ4E2b, KQ5E2b.23295899
180 Hides L, Quinn C, Cockshaw W, . Efficacy and outcomes of a mobile app targeting alcohol use in young people. Addict Behav. 2017;77:89–95. PMID: 28992580. KQ4E8, KQ5E8.28992580
181 Holliday J, Segrott J, Rothwell H, . Pragmatic trials of non-NHS interventions: Experiences from a Randomised Controlled Trial of the Strengthening Families 10-14 UK Programme (SFP10-14 UK). Trials. 2011;12. KQ4E5e, KQ5E5e.
182 Hore B, Alsafar J, Wilkins R. An attempt at criterion-oriented validation of an alcoholism questionnaire in general practice. Br J Addict Alcohol Other Drugs. 1977:7219–22. KQ2E5b.
183 Humeniuk R, Ali R, Babor TF, . Validation of the Alcohol, Smoking And Substance Involvement Screening Test (ASSIST). Addiction. 2008;103(6):1039–47. PMID: 18373724. KQ2E2b.18373724
184 Ingels JB, Corso PS, Kogan SM, . Cost-effectiveness of the strong African American families-teen program: 1-year follow-up. Drug Alcohol Depend. 2013;133(2):556–61. PMID: 23998376. KQ4E5e, KQ5E5e.23998376
185 Ingersoll KS, Ceperich SD, Hettema JE, . Preconceptional motivational interviewing interventions to reduce alcohol-exposed pregnancy risk. J Subst Abuse Treat. 2013;44(4):407–16. PMID: 23192220. KQ4E3a, KQ5E3a.23192220
186 Ip P, Chan KL, Chow CB, . An Internet-Based Intervention to Promote Alcohol-Related Attitudinal and Behavioral Change Among Adolescents: Protocol of a Cluster Randomized Controlled Trial. JMIR Res Protoc. 2016;5(2):e103. PMID: 27252072. KQ4E2a, KQ5E2a.27252072
187 Israel Y, Hollander O, Sanchez-Craig M, . Screening for problem drinking and counseling by the primary care physician-nurse team. Alcohol Clin Exp Res. 1996;20(8):1443–50. KQ4E9, KQ5E9.8947323
188 Ivanets NN, Lukomskaya MI. Evaluation of early intervention strategies used in primary health care: a report on the World Health Organization (WHO) Project on Identification and Treatment of Persons with Harmful Alcohol Consumption. Alcohol Alcohol Suppl. 1991;1:489–91. KQ4E2a, KQ5E2a.1845584
189 Jalling C, Bodin M, Romelsjo A, . Parent Programs for Reducing Adolescent’s Antisocial Behavior and Substance Use: A Randomized Controlled Trial. J Child Fam Stud. 2016;25:811–26. PMID: 26900316. KQ4E3a, KQ5E3a.26900316
190 Jander A, Crutzen R, Mercken L, . A Web-based computer-tailored game to reduce binge drinking among 16 to 18 year old Dutch adolescents: development and study protocol. BMC Public Health. 2014;14:1054. PMID: 25301695. KQ4E5e, KQ5E5e.25301695
191 Jensen MR, Wong JJ, Gonzales NA, . Long-term effects of a universal family intervention: mediation through parent-adolescent conflict. Journal of Clinical Child & Adolescent Psychology. 2014;43(3):415–27. PMID: 24730357. KQ4E5e, KQ5E5e.24730357
192 Jeong HS, Park S, Lim SM, . Psychometric Properties of the Alcohol Use Disorders Identification Test-Consumption (AUDIT-C) in Public First Responders. Subst Use Misuse. 2017;52(8):1069–75. PMID: 28323556. KQ2E3b.28323556
193 JF K, E G, T P, . Reliabilities of short substance abuse screening tests among adolescent medical patients. Pediatrics. 2000;105:948–53. KQ2E4.10742352
194 Johnson NA, Kypri K, Saunders JB, . The hospital outpatient alcohol project (HOAP): protocol for an individually randomized, parallel-group superiority trial of electronic alcohol screening and brief intervention versus screening alone for unhealthy alcohol use. Addict Sci Clin Pract. 2013;8:14. PMID: 24004498. KQ4E4, KQ5E4.24004498
195 Kaner EF, Beyer F, Dickinson HO, . Effectiveness of brief alcohol interventions in primary care populations. Cochrane Database Syst Rev. 2007(2):CD004148. PMID: 17443541. KQ4E9, KQ5E9.17443541
196 Kay-Lambkin FJ, Baker AL, Geddes J, . The iTreAD project: a study protocol for a randomised controlled clinical trial of online treatment and social networking for binge drinking and depression in young people. BMC Public Health. 2015;15:1025. PMID: 26444863. KQ4E3a, KQ5E3a.26444863
197 Kay-Lambkin FJ, Baker AL, Lewin TJ, . Computer-based psychological treatment for comorbid depression and problematic alcohol and/or cannabis use: a randomized controlled trial of clinical efficacy. Addiction. 2009;104(3):378–88. KQ4E3a, KQ5E3a.19207345
198 Kazemi D, Dmochowski J, Linman S, . Outcomes of a Targeted Capacity Expansion (TCE) brief motivational intervention for high-risk drinking freshmen: Pilot study comparison at baseline and 6 months. Alcoholism Treatment Quarterly. 2011;29(3):219–29. PMID: None. KQ4E3a, KQ5E3a.
199 Keurhorst MN, Anderson P, Spak F, . Implementing training and support, financial reimbursement, and referral to an internet-based brief advice program to improve the early identification of hazardous and harmful alcohol consumption in primary care (ODHIN): study protocol for a cluster randomized factorial trial. Implement Sci. 2013;8:11. PMID: 23347874. KQ4E4, KQ5E4.23347874
200 Khadjesari Z, Murray E, Kalaitzaki E, . Test-retest reliability of an online measure of past week alcohol consumption (the TOT-AL), and comparison with face-to-face interview. Addict Behav. 2009;34(4):337–42. KQ2E9.19097705
201 Khadjesari Z, White IR, McCambridge J, . Validation of the AUDIT-C in adults seeking help with their drinking online. Addict Sci Clin Pract. 2017;12(1):2. PMID: 28049515. KQ2E3a.28049515
202 Khan R, Chatton A, Nallet A, . Validation of the French version of the alcohol, smoking and substance involvement screening test (ASSIST). Eur Addict Res. 2011;17(4):190–7. PMID: 21494047. KQ2E2b.21494047
203 Kills Small NJ, Simons JS, Stricherz M. Assessing criterion validity of the Simple Screening Instrument for Alcohol and Other Drug Abuse (SSI-AOD) in a college population. Addict Behav. 2007;32(10):2425–31. PMID: 17481826. KQ2E3a.17481826
204 Kim CG, Kim JS, Jung JG, . Reliability and Validity of Alcohol Use Disorder dentification Test-Korean Revised Version for Screening At-risk Drinking and Alcohol Use Disorders. Korean J Fam Med. 2014;35(1):2–10. PMID: 24501664. KQ2E10.24501664
205 Kim JW, Lee BC, Lee DY, . The 5-item Alcohol Use Disorders Identification Test (AUDIT-5): an effective brief screening test for problem drinking, alcohol use disorders and alcohol dependence. Alcohol Alcohol. 2013;48(1):68–73. PMID: 22917753. KQ2E9.22917753
206 Kirisci L, Reynolds M, Tarter R. Quick Screen to Detect Current and Future Substance Use Disorder in Female Adolescents. International Journal of Person Centered Medicine. 2013;3(4):280–5. PMID: 25089182. KQ2E1.25089182
207 Kivlahan DR, Marlatt GA, Fromme K, . Secondary prevention with college drinkers: evaluation of an alcohol skills training program. J Consult Clin Psychol. 1990;58(6):805–10. KQ4E3a, KQ5E3a.2292630
208 Kolsek M, Poplas Susic T, Kersnik J. Slovenian adaptation of the original AUDIT-C questionnaire. Subst Use Misuse. 2013;48(8):581–9. PMID: 23750659. KQ2E6.23750659
209 Koning I, Eijnden R, Verdurmen J, . Long-term effects of a parent and student intervention on alcohol use in adolescents: a cluster randomized controlled trial. Am J Prev Med. 2011;40(5):541–7. KQ4E5e, KQ5E5e.21496753
210 Koning IM, Vollebergh WA, Smit F, . Preventing heavy alcohol use in adolescents (PAS): cluster randomized trial of a parent and student intervention offered separately and simultaneously. Addiction. 2009;104(10):1669–78. PMID: 21265908. KQ4E5e, KQ5E5e.21265908
211 Korcha RA, Cherpitel CJ, Moskalewicz J, . Readiness to change, drinking, and negative consequences among Polish SBIRT patients. Addict Behav. 2012;37(3):287–92. PMID: 22119521. KQ4E2c, KQ5E2c.22119521
212 Kulesza M, McVay MA, Larimer ME, . A randomized clinical trial comparing the efficacy of two active conditions of a brief intervention for heavy college drinkers. Addict Behav. 2013;38(4):2094–101. PMID: 23410849. KQ4E8, KQ5E8.23410849
213 Kumpfer KL, Whiteside HO, Greene JA, . Effectiveness outcomes of four age versions of the Strengthening Families Program in statewide field sites. Group Dynamics: Theory, Research, and Practice. 2010;14(3):211–29. KQ4E5e, KQ5E5e.
214 Kwon US, Kim JS, Kim SS, . Utility of the Alcohol Consumption Questions in the Alcohol Use Disorders Identification Test for Screening At-Risk Drinking and Alcohol Use Disorders among Korean College Students. Korean J Fam Med. 2013;34(4):272–80. PMID: 23904957. KQ2E10.23904957
215 Kypri K, McCambridge J, Vater T, . Web-based alcohol intervention for Maori university students: double-blind, multi-site randomized controlled trial. Addiction. 2013;108(2):331–8. PMID: 22925046. KQ4E8, KQ5E8.22925046
216 Kypri K, Vater T, Bowe SJ, . Web-based alcohol screening and brief intervention for university students: a randomized trial. JAMA. 2014;311(12):1218–24. PMID: 24668103. KQ4E8, KQ5E8.24668103
217 L B, Francis G, K L. The RAFFT as a screening tool for adolescent substance use disorders. Am J Addict. 2000;9:10–6. KQ2E3a.10914289
218 LaBrie JW, Napper LE, Grimaldi EM, . The efficacy of a standalone protective behavioral strategies intervention for students accessing mental health services. Prev Sci. 2015;16(5):663–73. PMID: 25728042. KQ4E3a, KQ5E3a.25728042
219 Lake SL, Hill-Kapturczak N, Liang Y, . Assessing the validity of participant-derived compared to staff-derived values to compute a binge score. Alcohol Alcohol. 2015;50(4):413–9. KQ2E5b.25770137
220 Lammers J, Goossens F, Conrod P, . Effectiveness of a selective intervention program targeting personality risk factors for alcohol misuse among young adolescents: Results of a cluster randomized controlled trial. Addiction. 2015;110(7):1101–9. KQ4E5e, KQ5E5e.25892544
221 Lapham GT, Rubinsky AD, Williams EC, . Decreasing sensitivity of clinical alcohol screening with the AUDIT-C after repeated negative screens in VA clinics. Drug Alcohol Depend. 2014;142:209–15. PMID: 25034900. KQ2E6.25034900
222 Lane WG, Dubowitz H, Feigelman S, . Screening for parental substance abuse in pediatric primary care. Ambul Pediatr. 2007;7(6):458–62. PMID: 17996841. KQ2E5b.17996841
223 Laux JM, Newman I, Brown R. The Michigan Alcoholism Screening Test (MAST): A Statistical Validation Analysis. Measurement and Evaluation in Counseling and Development. 2004;36(4):209–25. KQ2E3a.
224 Lee CS, Colby SM, Magill M, . A randomized controlled trial of culturally adapted motivational interviewing for Hispanic heavy drinkers: Theory of adaptation and study protocol. Contemp Clin Trials. 2016;50:193–200. PMID: 27565832. KQ4E3a, KQ5E3a.27565832
225 Lee HS, Mericle AA, Ayalon L, . Harm reduction among at-risk elderly drinkers: a site-specific analysis from the multi-site Primary Care Research in Substance Abuse and Mental Health for Elderly (PRISM-E) study. Int J Geriatr Psychiatry. 2009;24(1):54–60. PMID: 18613283. KQ4E6, KQ5E6.18613283
226 Lee JD, Delbanco B, Wu E, . Substance use prevalence and screening instrument comparisons in urban primary care. Subst Abus. 2011;32(3):128–34. PMID: 21660872. KQ2E6.21660872
227 Leonardson GR, Kemper E, Ness FK, . Validity and reliability of the audit and CAGE-AID in Northern Plains American Indians. Psychological reports. 2005;97(1):161–6. PMID: 16279320. KQ2E6.16279320
228 Lock CA, Kaner E, Heather N, . Effectiveness of nurse-led brief alcohol intervention: a cluster randomized controlled trial. J Adv Nurs. 2006;54(4):426–39. PMID: 16671972. KQ4E10, KQ5E10.16671972
229 Lopez ML, Iglesias JM, del Valle MO, . Impact of a primary care intervention on smoking, drinking, diet, weight, sun exposure, and work risk in families with cancer experience. Cancer Causes Control. 2007;18(5):525–35. PMID: 17450417. KQ1E5e, KQ3E5e.17450417
230 Louis M, Ricketson J, Wishart I. What is the accuracy of screening instruments for alcohol and cannabis misuse disorders among adolescents and young adults in the emergency department? Ann Emerg Med. 2013;61(4):404–6. PMID: 23102852. KQ2E2c.23102852
231 Lundin A, Hallgren M, Balliu N, . The use of alcohol use disorders identification test (AUDIT) in detecting alcohol use disorder and risk drinking in the general population: validation of AUDIT using schedules for clinical assessment in neuropsychiatry. Alcoholism: Clinical & Experimental Research. 2015;39(1):158–65. PMID: 25623414. KQ2E3a.25623414
232 Marsiglia FF, Ayers SL, Baldwin-White A, . Changing Latino Adolescents’ Substance Use Norms and Behaviors: the Effects of Synchronized Youth and Parent Drug Use Prevention Interventions. Prev Sci. 2016;17(1):1–12. PMID: 26103920. KQ4E5e, KQ5E5e.26103920
233 Martens MP, Cadigan JM, Rogers RE, . Personalized drinking feedback intervention for veterans of the wars in Iraq and Afghanistan: a randomized controlled trial. Journal of Studies on Alcohol & Drugs. 2015;76(3):355–9. PMID: 25978820. KQ4E10, KQ5E10.25978820
234 Martens MP, Smith AE, Murphy JG. The efficacy of single-component brief motivational interventions among at-risk college drinkers. Journal of Consulting & Clinical Psychology. 2013;81(4):691–701. PMID: 23506464. KQ4E6, KQ5E6.23506464
235 Mason WA, Haggerty K, Fleming A, . Family intervention to prevent depression and substance use among adolescents of depressed parents. J Child Fam Stud. 2012;21(6):891–905. PMID: None. KQ4E5e, KQ5E5e.23798891
236 McCambridge J, Day M. Randomized controlled trial of the effects of completing the Alcohol Use Disorders Identification Test questionnaire on self-reported hazardous drinking. Addiction. 2008;103(2):241–8. KQ1E8, KQ3E8.18199302
237 McCambridge J, Thomas BA. Short forms of the AUDIT in a Web-based study of young drinkers. Drug Alcohol Rev. 2009;28(1):18–24. PMID: 19320671. KQ2E6.19320671
238 McClatchey K, Boyce M, Dombrowski SU. Alcohol Brief Intervention in a university setting: A small-scale experimental study. Journal of health psychology. 2015. PMID: 26721632. KQ4E8, KQ5E8.26721632
239 McDevitt-Murphy ME, Murphy JG, Williams JL, . Randomized controlled trial of two brief alcohol interventions for OEF/OIF veterans. J Consult Clin Psychol. 2014;82(4):562–8. PMID: 24773573. KQ4E6, KQ5E6.24773573
240 McIntosh MC, Leigh G, Baldwin NJ, . Reducing alcohol consumption. Comparing three brief methods in family practice. Canadian family physician Medecin de famille canadien. 1997;43:1959–62, 65–7. KQ4E10, KQ5E10.9386883
241 McMillen BA, Hillis SM, Brown JM. College students’ responses to a 5/4 drinking question and maximum blood alcohol concentration calculated from a Timeline Followback Questionnaire. J Stud Alcohol Drugs. 2009;70(4):601–5. KQ2E9.19515301
242 McQueen JM, Howe TE, Ballinger C, . Effectiveness of Alcohol Brief Intervention in a General Hospital: A Randomized Controlled Trial. Journal of Studies on Alcohol & Drugs. 2015;76(6):838–44. PMID: 26562591. KQ4E2b, KQ5E2b.26562591
243 Mello MJ, Baird J, Lee C, . A Randomized Controlled Trial of a Telephone Intervention for Alcohol Misuse With Injured Emergency Department Patients. Ann Emerg Med. 2016;67(2):263–75. PMID: 26585044. KQ4E2c, KQ5E2c.26585044
244 Michaud P, Kunz V, Demortiere G, . Efficiency of brief interventions on alcohol-related risks in occupational medicine. Glob Health Promot. 2013;20:(2 Suppl):99–105. PMID: 23678504. KQ4E2b, KQ5E2b.23678504
245 Milburn NG, Iribarren FJ, Rice E, . A family intervention to reduce sexual risk behavior, substance use, and delinquency among newly homeless youth. Journal of Adolescent Health. 2012;50(4):358–64. PMID: 22443839. KQ4E3a, KQ5E3a.22443839
246 Miller WR, Toscova RT, Miller JH, . A theory-based motivational approach for reducing alcohol/drug problems in college. Health education & behavior: the official publication of the Society for Public Health Education. 2000;27(6):744–59. PMID: 11104373. KQ4E5e, KQ5E5e.11104373
247 Montag AC, Brodine SK, Alcaraz JE, . Preventing alcohol-exposed pregnancy among an American Indian/Alaska Native population: effect of a screening, brief intervention, and referral to treatment intervention. Alcohol Clin Exp Res. 2015;39(1):126–35. PMID: 25623412. KQ1E5e, KQ3E5e.25623412
248 Moore AA, Beck JC, Babor TF, . Beyond alcoholism: identifying older, at-risk drinkers in primary care. J Stud Alcohol Drugs. 2002;63(3):316–24. PMID: 12086132. KQ2E5b.12086132
249 Moore M, Werch C. Efficacy of a brief alcohol consumption reintervention for adolescents. Subst Use Misuse. 2009;44(7):1009–20. KQ4E3a, KQ5E3a.19938941
250 Morley KC, Sitharthan G, Haber PS, . The efficacy of an opportunistic cognitive behavioral intervention package (OCB) on substance use and comorbid suicide risk: a multisite randomized controlled trial. Journal of Consulting & Clinical Psychology. 2014;82(1):130–40. PMID: 24364795. KQ4E3a, KQ5E3a.24364795
251 Morton JL, Jones TV, Manganaro MA. Performance of alcoholism screening questionnaires in elderly veterans. Am J Med. 1996;101(2):153–9. PMID: 8757354. KQ2E4.8757354
252 Moussas G, Dadouti G, Douzenis A, . The Alcohol Use Disorders Identification Test (AUDIT): reliability and validity of the Greek version. Ann Gen Psychiatry. 2009;8:11. PMID: 19442281. KQ2E9.19442281
253 Moyers TB, Houck J, Rice SL, . Therapist empathy, combined behavioral intervention, and alcohol outcomes in the COMBINE research project. J Consult Clin Psychol. 2016;84(3):221–9. KQ4E3a, KQ5E3a.26795938
254 Muench F, van Stolk-Cooke K, Kuerbis A, . A Randomized Controlled Pilot Trial of Different Mobile Messaging Interventions for Problem Drinking Compared to Weekly Drink Tracking. PloS one. 2017;12(2):e0167900. PMID: 28146560. KQ4E8, KQ5E8.28146560
255 Murphy JG, Benson TA, Vuchinich RE, . A comparison of personalized feedback for college student drinkers delivered with and without a motivational interview. J Stud Alcohol. 2004;65(2):200–3. PMID: 15151350. KQ4E6, KQ5E6.15151350
256 Murphy JG, Dennhardt AA, Skidmore JR, . A randomized controlled trial of a behavioral economic supplement to brief motivational interventions for college drinking. Journal of Consulting & Clinical Psychology. 2012;80(5):876–86. PMID: 22663899. KQ4E6, KQ5E6.22663899
257 Murphy JG, Duchnick JJ, Vuchinich RE, . Relative efficacy of a brief motivational intervention for college student drinkers. Psychol Addict Behav. 2001;15(4):373–9. PMID: 11767271. KQ4E3a, KQ5E3a.11767271
258 Nadkarni A, Weiss HA, Weobong B, . Sustained effectiveness and cost-effectiveness of Counselling for Alcohol Problems, a brief psychological treatment for harmful drinking in men, delivered by lay counsellors in primary care: 12-month follow-up of a randomised controlled trial. PLoS Med. 2017;14(9):e1002386. PMID: 28898239. KQ4E2a, KQ5E2a.28898239
259 Napper LE, LaBrie JW, Earle AM. Online personalized normative alcohol feedback for parents of first-year college students. Psychol Addict Behav. 2016;30(8):802–10. PMID: 27819429. KQ4E10, KQ5E10.27819429
260 Nct. Substance-use Focused Screening and Brief Intervention as a Complement to Internet-based Psychiatric Treatment for Depression, Panic Disorder or Social Phobia: A Randomized Controlled Trial (eScreeniPsy). Http://clinicaltrialsgov/show/NCT01885026. 2013. KQ4E4, KQ5E4.
261 Neff JA, Kelley ML, Walters ST, . Effectiveness of a Screening and Brief Intervention protocol for heavy drinkers in dental practice: A cluster-randomized trial. Journal of health psychology. 2015;20(12):1534–48. PMID: 24423575. KQ4E2b, KQ5E2b.24423575
262 Neff JA, Walters ST, Braitman AL, . A brief motivational intervention for heavy alcohol use in dental practice settings: Rationale and development. Journal of health psychology. 2013;18(4):542–53. PMID: 22837547. KQ4E2b, KQ5E2b.22837547
263 Nehlin C, Gronbladh L, Fredriksson A, . Brief alcohol intervention in a psychiatric outpatient setting: a randomized controlled study. Addict Sci Clin Pract. 2012;7:23. PMID: 23186026. KQ4E2b, KQ5E2b.23186026
264 Neumann T, Neuner B, Weiss-Gerlach E, . The effect of computerized tailored brief advice on at-risk drinking in subcritically injured trauma patients. The Journal of trauma. 2006;61(4):805–14. KQ4E2c, KQ5E2c.17033544
265 Newcombe D, Tanielu-Stowers H, McDermott R, . The validation of the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) amongst Pacific people in New Zealand. New Zealand Journal of Psychology. 2016;45(1):30–9. KQ2E4.
266 Newcombe DA, Humeniuk RE, Ali R. Validation of the World Health Organization Alcohol, Smoking and Substance Involvement Screening Test (ASSIST): report of results from the Australian site. Drug Alcohol Rev. 2005;24(3):217–26. PMID: 16096125. KQ4E2b, KQ5E2b.16096125
267 Nilssen O. The Tromso Study: identification of and a controlled intervention on a population of early-stage risk drinkers. Preventive medicine. 1991;20(4):518–28. KQ4E10, KQ5E10.1678518
268 Noknoy S, Rangsin R, Saengcharnchai P, . RCT of effectiveness of motivational enhancement therapy delivered by nurses for hazardous drinkers in primary care units in Thailand. Alcohol Alcohol. 2010;45(3):263–70. PMID: 20236990. KQ4E2a, KQ5E2a.20236990
269 Norman P, Cameron D, Epton T, . A randomized controlled trial of a brief online intervention to reduce alcohol consumption in new university students: Combining self-affirmation, theory of planned behaviour messages, and implementation intentions. Br J Health Psychol. 2017. PMID: 28941040. KQ4E10, KQ5E10.28941040
270 Ntouva A, Porter J, Crawford MJ, . Assessing the feasibility of screening and providing brief advice for alcohol misuse in general dental practice: a clustered randomised control trial protocol for the DART study. BMJ Open. 2015;5(10):e008586. PMID: 26443659. KQ4E2b, KQ5E2b.26443659
271 Nyamathi A, Branson C, Kennedy B, . Impact of nursing intervention on decreasing substances among homeless youth. Am J Addict. 2012;21(6):558–65. PMID: 23082836. KQ4E6, KQ5E6.23082836
272 O’Connor PG. Managing substance dependence as a chronic disease is the glass half full or half empty? JAMA: Journal of the American Medical Association. 2013;310(11):1132–4. KQ4E9, KQ5E9.24045739
273 O’Farrell TJ, Fals-Stewart W, Murphy M. Concurrent validity of a brief self-report drug use frequency measure. Addict Behav. 2003;28(2):327–37. KQ2E4.12573682
274 O’Leary-Barrett M, Castellanos-Ryan N, Pihl RO, . Mechanisms of personality-targeted intervention effects on adolescent alcohol misuse, internalizing and externalizing symptoms. J Consult Clin Psychol. 2016;84(5):438–52. PMID: 26881449. KQ4E5e, KQ5E5e.26881449
275 Osaki Y, Ino A, Matsushita S, . Reliability and validity of the alcohol use disorders identification test - consumption in screening for adults with alcohol use disorders and risky drinking in Japan. Asian Pac J Cancer Prev. 2014;15(16):6571–4. PMID: 25169489. KQ2E6.25169489
276 Oslin DW, Grantham S, Coakley E, . PRISM-E: comparison of integrated care and enhanced specialty referral in managing at-risk alcohol use. Psychiatric services. 2006;57(7):954–8. KQ4E6, KQ5E6.16816279
277 Osterman R, Lewis D, Winhusen T. Efficacy of motivational enhancement therapy to decrease alcohol and illicit-drug use in pregnant substance users reporting baseline alcohol use. J Subst Abuse Treat. 2017;77:150–5. PMID: 28254158. KQ4E3a, KQ5E3a.28254158
278 Osterman RL, Dyehouse J. Effects of a motivational interviewing intervention to decrease prenatal alcohol use. West J Nurs Res. 2012;34(4):434–54. PMID: 21540353. KQ4E10, KQ5E10.21540353
279 Paidisetty S, Gordon AJ. Pharmacologic management of alcohol use disorders in the primary care setting. JCOM. 2006;13(11). PMID: None. KQ4E5c, KQ5E5c.
280 Palfai TP, Zisserson R, Saitz R. Using personalized feedback to reduce alcohol use among hazardous drinking college students: the moderating effect of alcohol-related negative consequences. Addict Behav. 2011;36(5):539–42. PMID: 21295919. KQ4E8, KQ5E8.21295919
281 Palm A, Olofsson N, Danielsson I, . Motivational interviewing does not affect risk drinking among young women: A randomised, controlled intervention study in Swedish youth health centres. Scand J Public Health. 2016;44(6):611–8. PMID: 27289105. KQ1E10, KQ3E10.27289105
282 Pantin H, Prado G, Lopez B, . A randomized controlled trial of Familias Unidas for Hispanic adolescents with behavior problems. Psychosomatic medicine. 2009;71(9):987–95. KQ4E5e, KQ5E5e.19834053
283 Parrish DE, von Sternberg K, Castro Y, . Processes of Change in Preventing Alcohol Exposed Pregnancy: A Mediation Analysis. J Consult Clin Psychol. 2016. PMID: 27176661. KQ4E3a, KQ5E3a.27176661
284 Paschall MJ, Antin T, Ringwalt CL, . Effects of AlcoholEdu for college on alcohol-related problems among freshmen: a randomized multicampus trial. J Stud Alcohol Drugs. 2011;72(4):642–50. PMID: 21683046. KQ4E10, KQ5E10.21683046
285 Patten CA, Vickers KS, Offord KP, . Validation of the revised Self-Administered Alcohol Screening Test (SAAST-R). Am J Addict. 2006;15(6):409–21. PMID: 17182442. KQ2E5b.17182442
286 Pedersen ER. Brief online interventions targeting risk and protective factors for increased and problematic alcohol use among American college students studying abroad. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2013;74(3-B(E)): No Pagination Specified. KQ4E8, KQ5E8.
287 Pedersen ER, Marshall GN, Schell TL. Study protocol for a web-based personalized normative feedback alcohol intervention for young adult veterans. Addict Sci Clin Pract. 2016;11(1):6. PMID: 27036408. KQ4E3a, KQ5E3a.27036408
288 Pedersen ER, Neighbors C, Atkins DC, . Brief online interventions targeting risk and protective factors for increased and problematic alcohol use among American college students studying abroad. Psychol Addict Behav. 2017;31(2):220–30. PMID: 28080092. KQ4E8, KQ5E8.28080092
289 Pedersen ER, Parast L, Marshall GN, . A randomized controlled trial of a web-based, personalized normative feedback alcohol intervention for young-adult veterans. Journal of Consulting & Clinical Psychology. 2017;85(5):459–70. PMID: 28287799. KQ4E3a, KQ5E3a.28287799
290 Perrier-Menard E, Castellanos-Ryan N, O’Leary-Barrett M, . The impact of youth internalising and externalising symptom severity on the effectiveness of brief personality-targeted interventions for substance misuse: A cluster randomised trial. Addict Behav. 2017;75:138–44. PMID: 28734153. KQ4E2b, KQ5E2b.28734153
291 Persson J. Early intervention in patients with excessive alcohol consumption: a controlled study. Alcohol Alcohol Suppl. 1991;1:473–6. PMID: 1845580. KQ4E4, KQ5E4.1845580
292 Persson J, Magnusson PH. Early intervention in patients with excessive consumption of alcohol: a controlled study. Alcohol. 1989;6(5):403–8. KQ4E10, KQ5E10.2573364
293 Philpot M, Pearson N, Petratou V, . Screening for problem drinking in older people referred to a mental health service: a comparison of CAGE and AUDIT. Aging Ment Health. 2003;7(3):171–5. PMID: 12775396. KQ2E3a.12775396
294 Poblete F, Barticevic NA, Zuzulich MS, . A randomized controlled trial of a brief intervention for alcohol and drugs linked to the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) in primary health care in Chile. Addiction. 2017;112(8):1462–9. PMID: 28239995. KQ4E8, KQ5E8.28239995
295 Purcell BW. The performance and feasibility of three brief alcohol screening tools in a senior population. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2015;75(7-B(E)): No Pagination Specified. KQ2E5b.
296 Randall-James J, Wadd S, Edwards K, . Alcohol screening in people with cognitive impairment: An exploratory study. Journal of dual diagnosis. 2015;11(1):65–74. PMID: 25436900. KQ2E6.25436900
297 Rapp RC, Otto AL, Lane DT, . Improving linkage with substance abuse treatment using brief case management and motivational interviewing. Drug Alcohol Depend. 2008;94(1–3):172–82. PMID: 18242883. KQ4E3a, KQ5E3a.18242883
298 Reinholdz H, Fornazar R, Bendtsen P, . Comparison of systematic versus targeted screening for detection of risky drinking in primary care. Alcohol Alcohol. 2013;48(2):172–9. PMID: 23299569. KQ1E4, KQ3E4.23299569
299 Rhee H, Hollen PJ, Belyea MJ, . Decision-making program for rural adolescents with asthma: a pilot study. Journal of pediatric nursing. 2008;23(6):439–50. PMID: 19026912. KQ4E5e, KQ5E5e.19026912
300 Rhodes KV, Rodgers M, Sommers M, . Brief Motivational Intervention for Intimate Partner Violence and Heavy Drinking in the Emergency Department: A Randomized Clinical Trial. JAMA. 2015;314(5):466–77. PMID: 26241598. KQ4E2c, KQ5E2c.26241598
301 Ridout B, Campbell A. Using Facebook to deliver a social norm intervention to reduce problem drinking at university. Drug Alcohol Rev. 2014;33(6):667–73. PMID: 24689339. KQ4E8, KQ5E8.24689339
302 Robertson I, Heather N, Dzialdowski A, . A comparison of minimal versus intensive controlled drinking treatment interventions for problem drinkers. Br J Clin Psychol. 1986;25 (Pt 3):185–94. KQ4E6, KQ5E6.3768576
303 Robin RW, Saremi A, Albaugh B, . Validity of the SMAST in two American Indian tribal populations. Subst Use Misuse. 2004;39(4):601–24. PMID: 15115215. KQ2E5b.15115215
304 Roderick P, S SS, Dimitrov BD, . Assessing feasibility and acceptability of a brief intervention for risky alcohol consumption in sexual health clinic attendees: a randomised controlled trial. J Fam Plann Reprod Health Care. 2016;42(2):143–51. PMID: 26259896. KQ4E10, KQ5E10.26259896
305 Romelsjo A, Andersson L, Barrner H, . A randomized study of secondary prevention of early stage problem drinkers in primary health care. Br J Addict. 1989;84(11):1319–27. KQ4E10, KQ5E10.2597808
306 Romo L, Le Strat Y, Aubry C, . The role of brief motivational intervention on self-efficacy and abstinence in a cohort of patients with alcohol dependence. International journal of psychiatry in medicine. 2009;39(3):313–23. KQ4E3b, KQ5E3b.19967902
307 Rose GL, Guth SE, Badger GJ, . Brief Intervention for Heavy Drinking in Primary Care: Role of Patient Initiation. J Addict Med. 2015;9(5):368–75. PMID: 26083959. KQ4E3a, KQ5E3a.26083959
308 Rouhbakhsh P. Screening for problem drinking in women. (substance abuse, alcohol use). Dissertation Abstracts International: Section B: The Sciences and Engineering. 1999;60(6-B):2959. KQ2E5b.
309 Rubio Valldolid G, Martinez-Raga J, Martinez-Gras I, . Validation of the Spanish version of the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST). Psicothema. 2014;26(2):180–5. PMID: 24755018. KQ4E2b, KQ5E2b.24755018
310 Rumpf HJ, Hapke U, Hill A, . Development of a screening questionnaire for the general hospital and general practices. Alcohol Clin Exp Res. 1997;21(5):894–8. PMID: 9267540. KQ2E5b.9267540
311 Russell M, Martier SS, Sokol RJ, . Screening for pregnancy risk-drinking. Alcohol Clin Exp Res. 1994;18(5):1156–61. PMID: 7847599. KQ2E10.7847599
312 Russell M, Martier SS, Sokol RJ, . Detecting risk drinking during pregnancy: a comparison of four screening questionnaires. Am J Public Health. 1996;86(10):1435–9. PMID: 8876514. KQ2E10.8876514
313 Rydon P, Redman S, Sanson-Fisher RW, . Detection of alcohol-related problems in general practice. J Stud Alcohol. 1992;53(3):197–202. PMID: 1583898. KQ4E9, KQ5E9.1583898
314 Ryou YI, Kim JS, Jung JG, . Usefulness of Alcohol-screening Instruments in Detecting Problem Drinking among Elderly Male Drinkers. Korean J Fam Med. 2012;33(3):126–33. PMID: 22787534. KQ2E10.22787534
315 S L, L S, SK H, . Test-retest reliability of adolescents’ self-report of substance use. Alcohol Clin Exp Res. 2004;28:1236–41. KQ2E4.15318123
316 Salvalaggio G, Dong K, Vandenberghe C, . Enhancing screening, brief intervention, and referral to treatment among socioeconomically disadvantaged patients: study protocol for a knowledge exchange intervention involving patients and physicians. BMC Health Serv Res. 2013;13:108. PMID: 23517813. KQ4E3a, KQ5E3a.23517813
317 Sanatinia R, Barrett B, Byford S, . Brief intervention for alcohol misuse in people attending sexual health clinics: study protocol for a randomized controlled trial. Trials. 2012;13:149. PMID: 22920408. KQ4E4, KQ5E4.22920408
318 Sanci L, Chondros P, Sawyer S, . Responding to Young People’s Health Risks in Primary Care: A Cluster Randomised Trial of Training Clinicians in Screening and Motivational Interviewing. PloS one. 2015;10(9):e0137581. PMID: 26422235. KQ1E10, KQ3E10.26422235
319 Sarkar M, Einarson T, Koren G. Comparing the effectiveness of TWEAK and T-ACE in determining problem drinkers in pregnancy. Alcohol Alcohol. 2010;45(4):356–60. PMID: 20497951. KQ2E3a.20497951
320 Satre DD, Delucchi K, Lichtmacher J, . Motivational interviewing to reduce hazardous drinking and drug use among depression patients. J Subst Abuse Treat. 2013;44(3):323–9. PMID: 22999815. KQ4E3a, KQ5E3a.22999815
321 Satre DD, Leibowitz A, Sterling SA, . A randomized clinical trial of Motivational Interviewing to reduce alcohol and drug use among patients with depression. Journal of Consulting & Clinical Psychology. 2016;84(7):571–9. PMID: 26985728. KQ4E3a, KQ5E3a.26985728
322 Saunders JB, Aasland OG, Babor TF, . Development of the Alcohol Use Disorders Identification Test (AUDIT): WHO Collaborative Project on Early Detection of Persons with Harmful Alcohol Consumption-II. Addiction. 1993;88(6):791–804. PMID: 8329970. KQ2E9.8329970
323 Schaub MP, Blankers M, Lehr D, . Efficacy of an internet-based self-help intervention to reduce co-occurring alcohol misuse and depression symptoms in adults: study protocol of a three-arm randomised controlled trial. BMJ Open. 2016;6(5):e011457. PMID: 27225652. KQ4E3a, KQ5E3a.27225652
324 Schaub MP, Tiburcio M, Martinez N, . Alcohol e-Help: Study protocol for a Web-based self-help program to reduce alcohol use in adults with drinking patterns considered harmful, hazardous, or suggestive of dependence in middle-income countries. Addiction. 2017. PMID: 28921778. KQ4E2a, KQ5E2a.28921778
325 Schinke SP, Fang L, Cole KC. Preventing substance use among adolescent girls: 1-year outcomes of a computerized, mother-daughter program. Addict Behav. 2009;34(12):1060–4. PMID: 19632053. KQ4E5e, KQ5E5e.19632053
326 Schinke SP, Fang L, Cole KC. Computer-delivered, parent-involvement intervention to prevent substance use among adolescent girls. Preventive medicine. 2009;49(5):429–35. PMID: 19682490. KQ4E5e, KQ5E5e.19682490
327 Schinke SP, Schwinn TM, Di Noia J, . Reducing the risks of alcohol use among urban youth: three-year effects of a computer-based intervention with and without parent involvement. J Stud Alcohol. 2004;65(4):443–9. PMID: 15376818. KQ4E5e, KQ5E5e.15376818
328 Schmidt A, Barry KL, Fleming MF. Detection of problem drinkers: the Alcohol Use Disorders Identification Test (AUDIT). Southern medical journal. 1995;88(1):52–9. PMID: 7817228. KQ2E4.7817228
329 Schonfeld L, King-Kallimanis B, Duchene D, . Screening and brief intervention for substance misuse among older adults: the Florida BRITE project. Am J Public Health. 2010;100(1):108–14. PMID: 19443821. KQ4E9, KQ5E9.19443821
330 Schuckit M, Kalmijn J, Smith T, . Structuring a college alcohol prevention program on the low level of response to alcohol model: a pilot study. Alcohol Clin Exp Res. 2012;36(7):1244–52. KQ4E6, KQ5E6.22309202
331 Scifres SL. Screening for problematic drinking in women: Validity of the Michigan Alcoholism Screening Test (MAST). Dissertation Abstracts International: Section B: The Sciences and Engineering. 2003;63(8-B):3937. KQ2E5b.
332 Segrott J, Gillespie D, Holliday J, . Preventing substance misuse: study protocol for a randomised controlled trial of the Strengthening Families Programme 10-14 UK (SFP 10-14 UK). BMC Public Health. 2014;14:49. PMID: 24438460. KQ4E5e, KQ5E5e.24438460
333 Seib CA, Daglish M, Heath R, . Screening for alcohol and drug use in pregnancy. Midwifery. 2012;28(6):760–4. PMID: 21940079. KQ2E6.21940079
334 Selin KH. Alcohol Use Disorder Identification Test (AUDIT): what does it screen? Performance of the AUDIT against four different criteria in a Swedish population sample. Subst Use Misuse. 2006;41(14):1881–99. PMID: 17162595. KQ2E9.17162595
335 Sellman JD, Sullivan PF, Dore GM, . A randomized controlled trial of motivational enhancement therapy (MET) for mild to moderate alcohol dependence. J Stud Alcohol. 2001;62(3):389–96. KQ4E3a, KQ5E3a.11414349
336 Sheehan J, Gill A, Kelly B. The effectiveness of a brief intervention to reduce alcohol consumption in pregnancy: A controlled trial. Irish journal of psychological medicine. 2014;31(3):175–89. KQ4E10, KQ5E10.30189489
337 Sillanaukee P, Aalto M, Seppa K. Carbohydrate-deficient transferrin and conventional alcohol markers as indicators for brief intervention among heavy drinkers in primary health care. Alcohol Clin Exp Res. 1998;22(4):892–6. PMID: 9660318. KQ2E6.9660318
338 Sinadinovic K, Berman AH, Hasson D, . Internet-based assessment and self-monitoring of problematic alcohol and drug use. Addict Behav. 2010;35(5):464–70. KQ2E4.20092953
339 Sinadinovic K, Wennberg P, Berman AH. Targeting problematic users of illicit drugs with Internet-based screening and brief intervention: a randomized controlled trial. Drug Alcohol Depend. 2012;126(1–2):42–50. PMID: 22613182. KQ4E3a, KQ5E3a.22613182
340 Skarstrand E, Sundell K, Andreasson S. Evaluation of a Swedish version of the Strengthening Families Programme. European journal of public health. 2014;24(4):578–84. PMID: 24078373. KQ4E5e, KQ5E5e.24078373
341 Skinner HA. The drug abuse screening test. Addict Behav. 1982;7(4):363–71. PMID: 7183189. KQ2E4.7183189
342 Slesnick N, Tonigan J. Assessment of Alcohol and Other Drug Use by Runaway Youths: A Test-Retest Study of the Form 90. Alcoholism Treatment Quarterly. 2004;22(2):21–34. KQ2E4.18563208
343 Smith DC, Bennett KM, Dennis ML, . Sensitivity and specificity of the gain short-screener for predicting substance use disorders in a large national sample of emerging adults. Addict Behav. 2017;68:14–7. PMID: 28088053. KQ2E3a.28088053
344 Snow M, Thurber S, Hodgson JM. An adolescent version of the Michigan Alcoholism Screening Test. Adolescence. 2002;37(148):835–40. PMID: 12564833. KQ2E9.12564833
345 So K, Sung E. A Validation Study of the Brief Alcohol Use Disorder Identification Test (AUDIT): A Brief Screening Tool Derived from the AUDIT. Korean J Fam Med. 2013;34(1):11–8. PMID: 23372901. KQ2E5b.23372901
346 Sogaard Nielsen A, Nielsen B, Andersen K, . The RESCueH Programme: Testing New Non-Pharmacologic Interventions for Alcohol Use Disorders: Rationale and Methods. Eur Addict Res. 2016;22(6):306–17. PMID: 27434091. KQ4E4, KQ5E4.27434091
347 Sokol RJ, Martier SS, Ager JW. The T-ACE questions: practical prenatal detection of risk-drinking. Am J Obstet Gynecol. 1989;160(4):863–8; discussion 8–70. PMID: 2712118. KQ2E9.2712118
348 Spivak K, Sanchez-Craig M, Davila R. Assisting problem drinkers to change on their own: effect of specific and non-specific advice. Addiction. 1994;89(9):1135–42. KQ4E3a, KQ5E3a.7987190
349 Spoth R, Redmond C, Shin C, . PROSPER community-university partnership delivery system effects on substance misuse through 6 1/2 years past baseline from a cluster randomized controlled intervention trial.[Erratum appears in Prev Med. 2014 Dec;69:36]. Preventive medicine. 2013;56(3–4):190–6. PMID: 23276777. KQ4E2b, KQ5E2b.23276777
350 Spoth R, Trudeau L, Redmond C, . Replication RCT of early universal prevention effects on young adult substance misuse. Journal of Consulting & Clinical Psychology. 2014;82(6):949–63. PMID: 24821095. KQ4E5e, KQ5E5e.24821095
351 Stein MD, Caviness CM, Morse EF, . A Developmental-based Motivational Intervention to Reduce Alcohol and Marijuana Use Among Non-Treatment-Seeking Young Adults: A Randomized Controlled Trial. Addiction. 2017. PMID: 28865169. KQ4E3a, KQ5E3a.28865169
352 Struzzo P, Scafato E, McGregor R, . A randomised controlled non-inferiority trial of primary care-based facilitated access to an alcohol reduction website (EFAR-FVG): the study protocol. BMJ Open. 2013;3(2). PMID: 23408073. KQ2E6.23408073
353 Suffoletto B, Callaway CW, Kristan J, . Mobile phone text message intervention to reduce binge drinking among young adults: study protocol for a randomized controlled trial. Trials. 2013;14:93. PMID: 23552023. KQ4E2c, KQ5E2c.23552023
354 Suffoletto B, Kristan J, Chung T, . An Interactive Text Message Intervention to Reduce Binge Drinking in Young Adults: A Randomized Controlled Trial with 9-Month Outcomes. PLoS ONE. 2015;10(11):e0142877. PMID: 26580802. KQ4E2c, KQ5E2c.26580802
355 Sundaram S, Roderick P, Frater A, . Assessing feasibility and acceptability of a brief intervention for risky alcohol consumption in sexual health clinic attendees. Int J STD AIDS. 2013;24:3. KQ4E10, KQ5E10.
356 Sundstrom C, Kraepelien M, Eek N, . High-intensity therapist-guided internet-based cognitive behavior therapy for alcohol use disorder: a pilot study. BMC psychiatry. 2017;17(1):197. PMID: 28549424. KQ4E3a, KQ5E3a.28549424
357 Tahaney KD, Palfai TP. Text messaging as an adjunct to a web-based intervention for college student alcohol use: A preliminary study. Addict Behav. 2017;73:63–6. PMID: 28478315. KQ4E8, KQ5E8.28478315
358 Tait RJ, Hulse GK, Robertson SI, . Emergency department-based intervention with adolescent substance users: 12-month outcomes. Drug Alcohol Depend. 2005;79(3):359–63. PMID: 16102378. KQ4E2c, KQ5E2c.16102378
359 Tait RJ, Teoh L, Kelty E, . Emergency department based intervention with adolescent substance users: 10year economic and health outcomes. Drug Alcohol Depend. 2016;165:168–74. PMID: 27317044. KQ4E2c, KQ5E2c.27317044
360 Taj N, Devera-Sales A, Vinson DC. Screening for problem drinking: does a single question work? J Fam Pract. 1998;46(4):328–35. PMID: 9564375. KQ2E9.9564375
361 Tariq L, van den Berg M, Hoogenveen RT, . Cost-effectiveness of an opportunistic screening programme and brief intervention for excessive alcohol use in primary care. PLoS ONE. 2009;4(5):e5696. PMID: 19479081. KQ4E9, KQ5E9.19479081
362 Terlecki M, Buckner J, Larimer M, . The Role of Social Anxiety in a Brief Alcohol Intervention for Heavy-Drinking College Students. Journal of cognitive psychotherapy. 2011;25(1):7–21. PMID: None. KQ4E8, KQ5E8.
363 Theobald H, Bygren LO, Carstensen J, . Validity of two questions on alcohol use in a health survey questionnaire. Scand J Public Health. 1999;27(1):73–7. PMID: 10847675. KQ2E10.10847675
364 Thomas K, Bendtsen M, Linderoth C, . Short message service (SMS)-based intervention targeting alcohol consumption among university students: study protocol of a randomized controlled trial. Trials. 2017;18(1):156. PMID: 28372563. KQ4E8, KQ5E8.28372563
365 Thompson RG, Jr., Elliott JC, Hu MC, . Short-term effects of a brief intervention to reduce alcohol use and sexual risk among homeless young adults: Results from a randomized controlled trial. Addict Res Theory. 2017;25(1):24–31. PMID: 28620272. KQ4E8, KQ5E8.28620272
366 Thush C, Wiers RW, Theunissen N, . A randomized clinical trial of a targeted intervention to moderate alcohol use and alcohol-related problems in at-risk adolescents. Pharmacology, biochemistry, and behavior. 2007;86(2):368–76. KQ4E3a, KQ5E3a.
367 Tirrell CA. Concurrent validity of the MMPI-A substance abuse scales: MAC-R, ACK, and PRO. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2005;65(9-B):4893. KQ2E5a.
368 Toll BA, Martino S, O’Malley SS, . A randomized trial for hazardous drinking and smoking cessation for callers to a quitline. Journal of Consulting & Clinical Psychology. 2015;83(3):445–54. PMID: 25419583. KQ4E10, KQ5E10.25419583
369 Tomson Y, Romelsjo A, Aberg H. Excessive drinking-brief intervention by a primary health care nurse. A randomized controlled trial. Scandinavian journal of primary health care. 1998;16(3):188–92. KQ4E10, KQ5E10.9800234
370 Turrisi R, Jaccard J, Taki R, . Examination of the short-term efficacy of a parent intervention to reduce college student drinking tendencies. Psychol Addict Behav. 2001;15(4):366–72. PMID: 11767270. KQ4E5e, KQ5E5e.11767270
371 Tuunanen M, Aalto M, Seppa K. Binge drinking and its detection among middle-aged men using AUDIT, AUDIT-C and AUDIT-3. Drug & Alcohol Review. 2007;26(3):295–9. PMID: 17454019. KQ2E10.17454019
372 Tvaryanas AP, Maupin GM, White ED, . The performance of the AUDIT-C and the examination of risks associated with postdeployment alcohol misuse in Air Force Medical Service personnel. Military Psychology. 2017;29(4):327–35. KQ2E6.
373 van Deursen DS, Salemink E, Smit F, . Web-based cognitive bias modification for problem drinkers: protocol of a randomised controlled trial with a 2x2x2 factorial design. BMC Public Health. 2013;13:674. PMID: 23870532. KQ4E6, KQ5E6.23870532
374 Varvil-Weld L, Scaglione N, Cleveland MJ, . Optimizing timing and dosage: Does parent type moderate the effects of variations of a parent-based intervention to reduce college student drinking? Prev Sci. 2014;15(1):94–102. KQ4E8, KQ5E8.23404668
375 Velasquez MM, von Sternberg K, Parrish DE. CHOICES: an integrated behavioral intervention to prevent alcohol-exposed pregnancies among high-risk women in community settings. Soc Work Public Health. 2013;28(3–4):224–33. PMID: 23731416. KQ4E3a, KQ5E3a.23731416
376 Vinson DC, Devera-Sales A. Computer-Generated Written Behavioral Contracts with Problem Drinkers in Primary Medical Care. Subst Abus. 2000;21(4):215–22. KQ4E10, KQ5E10.12466660
377 Vinson DC, Kruse RL, Seale JP. Simplifying alcohol assessment: two questions to identify alcohol use disorders. Alcoholism: Clinical & Experimental Research. 2007;31(8):1392–8. PMID: 17559544. KQ2E5b.17559544
378 Vitesnikova J, Dinh M, Leonard E, . Use of AUDIT-C as a tool to identify hazardous alcohol consumption in admitted trauma patients. Injury. 2014;45(9):1440–4. PMID: 24629701. KQ2E2c.24629701
379 Voogt C, Kuntsche E, Kleinjan M, . Using ecological momentary assessment to test the effectiveness of a web-based brief alcohol intervention over time among heavy-drinking students: randomized controlled trial. J Med Internet Res. 2014;16(1):e5. PMID: 24401555. KQ4E2b, KQ5E2b.24401555
380 Voogt CV, Kleinjan M, Poelen EA, . The effectiveness of a web-based brief alcohol intervention in reducing heavy drinking among adolescents aged 15-20 years with a low educational background: a two-arm parallel group cluster randomized controlled trial. BMC Public Health. 2013;13:694. PMID: 23895403. KQ4E10, KQ5E10.23895403
381 Wade D, Varker T, Forbes D, . The Alcohol Use Disorders Identification Test-Consumption (AUDIT-C) in the assessment of alcohol use disorders among acute injury patients. Alcoholism: Clinical & Experimental Research. 2014;38(1):294–9. PMID: 24033497. KQ2E2c.24033497
382 Wagner EF, Hospital MM, Graziano JN, . A randomized controlled trial of guided self-change with minority adolescents. Journal of Consulting & Clinical Psychology. 2015;82(6):1128–39. PMID: 24841864. KQ4E3a, KQ5E3a.24841864
383 Walker DD, Walton TO, Neighbors C, . Randomized trial of motivational interviewing plus feedback for soldiers with untreated alcohol abuse. Journal of Consulting & Clinical Psychology. 2017;85(2):99–110. PMID: 27736113. KQ4E3a, KQ5E3a.27736113
384 Wallace P, Murray E, McCambridge J, . On-line randomized controlled trial of an internet based psychologically enhanced intervention for people with hazardous alcohol consumption. PloS one. 2011;6(3):e14740. KQ4E3a, KQ5E3a.21408060
385 Walters ST, Vader AM, Harris TR, . Dismantling motivational interviewing and feedback for college drinkers: a randomized clinical trial. J Consult Clin Psychol. 2009;77(1):64–73. KQ4E3a, KQ5E3a.19170454
386 Watson J, Tober G, Raistrick D, . An alcohol-focused intervention versus a healthy living intervention for problem drinkers identified in a general hospital setting (ADAPTA): study protocol for a randomized, controlled pilot trial. Trials. 2013;14:117. PMID: 23782907. KQ4E2b, KQ5E2b.23782907
387 Watson J, Toner P, Day E, . Youth social behaviour and network therapy (Y-SBNT): adaptation of a family and social network intervention for young people who misuse alcohol and drugs - a randomised controlled feasibility trial. Health Technol Assess. 2017;21(15):1–260. PMID: 28399988. KQ4E3a, KQ5E3a.28399988
388 Watson JM, Fairhurst C, Li J, . ADAPTA: A pilot randomised controlled trial of an alcohol-focused intervention versus a healthy living intervention for problem drinkers identified in a general hospital setting. Drug Alcohol Depend. 2015;154:117–24. PMID: 26194955. KQ4E2b, KQ5E2b.26194955
389 Werch CE, Moore MJ, Bian H, . Efficacy of a brief image-based multiple-behavior intervention for college students. Ann Behav Med. 2008;36(2):149–57. PMID: 18800217. KQ4E8, KQ5E8.18800217
390 Westermeyer J, Yargic I, Thuras P. Michigan assessment-screening test for alcohol and drugs (MAST/AD): evaluation in a clinical sample. Am J Addict. 2004;13(2):151–62. PMID: 15204666. KQ2E3a.15204666
391 Whetten K, Reif S, Swartz M, . A brief mental health and substance abuse screener for persons with HIV. AIDS Patient Care STDS. 2005;19(2):89–99. PMID: 15716640. KQ2E9.15716640
392 Whiteside U. A brief personalized feedback intervention integrating a motivational interviewing therapeutic style and dialectical behavioral therapy skills for depressed or anxious heavy drinking young adults. Dissertation abstracts international: section b: the sciences and engineering. 2011;71(12-b):7745. KQ4E8, KQ5E8.
393 Wiener C, Herring D, Dotson K, . Evaluation of a digitally-automated single session alcohol curriculum designed to alter expectancies and reduce alcohol use in college students. Alcohol Clin Exp Res. 2015;39:206a. KQ4E8, KQ5E8.
394 Wiggins M, Bonell C, Sawtell M, . Health outcomes of youth development programme in England: Prospective matched comparison study. BMJ. 2009;339(7713):148–51. KQ4E6, KQ5E6.
395 Williams E, Achtmeyer C, Kivlahan D, . Evaluation of an electronic clinical reminder to facilitate brief alcohol-counseling interventions in primary care. J Stud Alcohol Drugs. 2010;71(5):720–5. KQ4E10, KQ5E10.20731977
396 Williams R, Vinson DC. Validation of a single screening question for problem drinking. Journal of Family Practice. 2001;50(4):307–12. PMID: 11300981. KQ2E2c.11300981
397 Wilson CR, Sherritt L, Gates E, . Are clinical impressions of adolescent substance use accurate? Pediatrics. 2004;114(5):e536–40. PMID: 15520086. KQ2E1.15520086
398 Wilson GB, McGovern R, Antony G, . Brief intervention to reduce risky drinking in pregnancy: study protocol for a randomized controlled trial. Trials. 2012;13:174. PMID: 23006975. KQ4E4, KQ5E4.23006975
399 Wilton G, Moberg D, VanStelle K. Telephone vs. in-person brief intervention: Results from a clinical trial to reduce alcohol-exposed pregnancies. Alcohol Clin Exp Res. 2014;38:343a. KQ4E6, KQ5E6.
400 Winters KC, Kaminer Y. Screening and assessing adolescent substance use disorders in clinical populations. Journal of the American Academy of Child & Adolescent Psychiatry. 2008;47(7):740–4. PMID: 18574399. KQ2E9.18574399
401 Winters KC, Lee S, Botzet A, . One-year outcomes and mediators of a brief intervention for drug abusing adolescents. Psychol Addict Behav. 2014;28(2):464–74. PMID: 24955669. KQ4E3a, KQ5E3a.24955669
402 Woolard R, Baird J, Longabaugh R, . Project reduce: reducing alcohol and marijuana misuse: effects of a brief intervention in the emergency department. Addict Behav. 2013;38(3):1732–9. PMID: 23261491. KQ4E2c, KQ5E2c.23261491
403 Wurdak M, Kuntsche E, Wolstein J. Effectiveness of an email-based intervention helping parents to enhance alcohol-related parenting skills and reduce their children’s alcohol consumption-A randomised controlled trial. Drugs: Education, Prevention & Policy. 2017;24(2):144–51. KQ4E3a, KQ5E3a.
404 Wusthoff LE, Waal H, Grawe RW. The effectiveness of integrated treatment in patients with substance use disorders co-occurring with anxiety and/or depression-a group randomized trial. BMC psychiatry. 2014;14:67. PMID: 24597469. KQ4E2b, KQ5E2b.24597469
405 Wutzke SE, Conigrave KM, Saunders JB, . The long-term effectiveness of brief interventions for unsafe alcohol consumption: a 10-year follow-up. Addiction. 2002;97(6):665–75. KQ4E10, KQ5E10.12084136
406 Yates FE. The evaluation of a ‘co-operative counselling’ alcohol service which uses family and affected others to reach and influence problem drinkers. Br J Addict. 1988;83(11):1309–19. KQ4E3a, KQ5E3a.3233403
407 Yonkers K, Gotman N, Kershaw T, . Screening for prenatal substance use: development of the Substance Use Risk Profile-Pregnancy scale. Obstet Gynecol. 2010;116(4):827–33. PMID: 20859145. KQ2E6.20859145
408 Yurasek AM. A randomized controlled trial of a behavioral economic intervention for substance abuse in a diverse college sample. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2015;76(6-B(E)): No Pagination Specified. KQ4E6, KQ5E6.
409 Yurasek AM, Dennhardt AA, Murphy JG. A randomized controlled trial of a behavioral economic intervention for alcohol and marijuana use. Experimental & Clinical Psychopharmacology. 2015;23(5):332–8. PMID: 26191947. KQ4E6, KQ5E6.26191947
410 Zanjani F, Mavandadi S, TenHave T, . Longitudinal course of substance treatment benefits in older male veteran at-risk drinkers. The journals of gerontology Series A, Biological sciences and medical sciences. 2008;63(1):98–106. KQ4E6, KQ5E6.
411 Zill JM, Meyer B, Topp J, . Vorvida: study protocol of a randomized controlled trial testing the effectiveness of Internet-based self-help program for the reduction of alcohol consumption for adults. BMC psychiatry. 2016;16:19. PMID: 26822579. KQ4E3a, KQ5E3a.26822579