# Appendix E Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

KQ1, KQ3:

- No included studies

KQ2:

- Aalto M, Alho H, Halme JT, . AUDIT and its abbreviated versions in detecting heavy and binge drinking in a general population survey. Drug Alcohol Depend. 2009;103(1–2):25–9. PMID: 19395203. 10.1016/j.drugalcdep.2009.02.013 19395203
- Aalto M, Alho H, Halme JT, . The Alcohol Use Disorders Identification Test (AUDIT) and its derivatives in screening for heavy drinking among the elderly. Int J Geriatr Psychiatry. 2011;26(9):881–5. PMID: 20661878. 10.1002/gps.2498 20661878
- Aertgeerts B, Buntinx F, Bande-Knops J, . The value of CAGE, CUGE, and AUDIT in screening for alcohol abuse and dependence among college freshmen. Alcohol Clin Exp Res. 2000;24(1):53–7. PMID: 10656193. 10.1111/j.1530-0277.2000.tb04553.x 10656193
- Bartoli F, Crocamo C, Biagi E, . Clinical utility of a single-item test for DSM-5 alcohol use disorder among outpatients with anxiety and depressive disorders. Drug Alcohol Depend. 2016;165:283–7. PMID: 27318372. 10.1016/j.drugalcdep.2016.06.003 27318372
- Boschloo L, Vogelzangs N, Smit JH, . The performance of the Alcohol Use Disorder Identification Test (AUDIT) in detecting alcohol abuse and dependence in a population of depressed or anxious persons. J Affect Disord. 2010;126(3):441–6. PMID: 20537398. 10.1016/j.jad.2010.04.019 20537398
- Bradley KA, Bush KR, Epler AJ, . Two brief alcohol-screening tests from the Alcohol Use Disorders Identification Test (AUDIT): validation in a female Veterans Affairs patient population. Arch Intern Med. 2003;163(7):821–9. PMID: 12695273. 10.1001/archinte.163.7.821 12695273
  - Bush KR, Kivlahan DR, Davis TM, . The TWEAK is weak for alcohol screening among female Veterans Affairs outpatients. Alcohol Clin Exp Res. 2003;27(12):1971–8. PMID: 14691385. 10.1097/01.ALC.0000099262.50094.98 14691385
- Buchsbaum DG, Welsh J, Buchanan RG, . Screening for drinking problems by patient self-report. Even ‘safe’ levels may indicate a problem. Arch Intern Med. 1995;155(1):104–8. PMID: 7802509. 10.1001/archinte.1995.00430010112015 7802509
- Bull LB, Kvigne VL, Leonardson GR, . Validation of a self-administered questionnaire to screen for prenatal alcohol use in Northern Plains Indian women. Am J Prev Med. 1999;16(3):240–3. PMID: 10198664. 10.1016/S0749-3797(98)00158-5 10198664
- Chung T, Smith GT, Donovan JE, . Drinking frequency as a brief screen for adolescent alcohol problems. Pediatrics. 2012;129(2):205–12. PMID: 22218839. 10.1542/peds.2011-1828 22218839
- Clark DB, Martin CS, Chung T, . Screening for Underage Drinking and Diagnostic and Statistical Manual of Mental Disorders, 5th Edition Alcohol Use Disorder in Rural Primary Care Practice. J Pediatr. 2016;173:214–20. PMID: 27059911. 10.1016/j.jpeds.2016.02.047 27059911
- Clements R. A critical evaluation of several alcohol screening instruments using the CIDI-SAM as a criterion measure. Alcohol Clin Exp Res. 1998;22(5):985–93. PMID: 9726267. 10.1111/j.1530-0277.1998.tb03693.x 9726267
- Cook RL, Chung T, Kelly TM, . Alcohol screening in young persons attending a sexually transmitted disease clinic. Comparison of AUDIT, CRAFFT, and CAGE instruments. J Gen Intern Med. 2005;20(1):1–6. PMID: 15693920. 10.1111/j.1525-1497.2005.40052.x 15693920
- Crawford EF, Fulton JJ, Swinkels CM, . Diagnostic efficiency of the AUDIT-C in U.S. veterans with military service since September 11, 2001. Drug Alcohol Depend. 2013;132(1–2):101–6. PMID: 23465735. 10.1016/j.drugalcdep.2013.01.012 23465735
- D’Amico EJ, Parast L, Meredith LS, . Screening in Primary Care: What Is the Best Way to Identify At-Risk Youth for Substance Use? Pediatrics. 2016;138(6). PMID: 27940696. 10.1542/peds.2016-1717 27940696
- Dawson DA, Grant BF, Stinson FS, . Effectiveness of the derived Alcohol Use Disorders Identification Test (AUDIT-C) in screening for alcohol use disorders and risk drinking in the US general population. Alcohol Clin Exp Res. 2005;29(5):844–54. PMID: 15897730. 10.1097/01.ALC.0000164374.32229.A2 15897730
  - Dawson DA, Pulay AJ, Grant BF. A comparison of two single-item screeners for hazardous drinking and alcohol use disorder. Alcohol Clin Exp Res. 2010;34(2):364–74. PMID: 19951291. 10.1111/j.1530-0277.2009.01098.x 19951291
- Dawson DA, Smith SM, Saha TD, . Comparative performance of the AUDIT-C in screening for DSM-IV and DSM-5 alcohol use disorders. Drug Alcohol Depend. 2012;126(3):384–8. PMID: 22728044. 10.1016/j.drugalcdep.2012.05.029 22728044
- Degenhardt LJ, Conigrave KM, Wutzke SE, . The validity of an Australian modification of the AUDIT questionnaire. Drug Alcohol Rev. 2001;20(2):143–54. PMID: None. 10.1080/09595230120058533
- Demartini KS, Carey KB. Optimizing the use of the AUDIT for alcohol screening in college students. Psychol Assess. 2012;24(4):954–63. PMID: 22612646. 10.1037/a0028519 22612646
- Foxcroft DR, Smith LA, Thomas H, . Accuracy of Alcohol Use Disorders Identification Test for detecting problem drinking in 18-35 year-olds in England: method comparison study. Alcohol Alcohol. 2015;50(2):244–50. PMID: 25534931. 10.1093/alcalc/agu095 25534931
- Gache P, Michaud P, Landry U, . The Alcohol Use Disorders Identification Test (AUDIT) as a screening tool for excessive drinking in primary care: reliability and validity of a French version. Alcohol Clin Exp Res. 2005;29(11):2001–7. PMID: 16340457. 10.1097/01.alc.0000187034.58955.64 16340457
- Gomez A, Conde A, Santana JM, . Diagnostic usefulness of brief versions of Alcohol Use Disorders Identification Test (AUDIT) for detecting hazardous drinkers in primary care settings. J Stud Alcohol Drugs. 2005;66(2):305–8. PMID: 15957683. 10.15288/jsa.2005.66.305 15957683
- Gomez A, Conde A, Santana JM, . The diagnostic usefulness of AUDIT and AUDIT-C for detecting hazardous drinkers in the elderly. Aging Ment Health. 2006;10(5):558–61. PMID: 16938691. 10.1080/13607860600637729 16938691
- Gryczynski J, Kelly SM, Mitchell SG, . Validation and performance of the Alcohol, Smoking and Substance Involvement Screening Test (ASSIST) among adolescent primary care patients. Addiction. 2015;110(2):240–7. PMID: 25311148. 10.1111/add.12767 25311148
- Gual A, Segura L, Contel M, . Audit-3 and audit-4: effectiveness of two short forms of the alcohol use disorders identification test. Alcohol Alcohol. 2002;37(6):591–6. PMID: 12414553.12414553
- Harris SK, Knight JR, Jr., Van Hook S, . Adolescent substance use screening in primary care: Validity of computer self-administered versus clinician-administered screening. Subst Abus. 2016;37(1):197–203. PMID: 25774878. 10.1080/08897077.2015.1014615 25774878
- Kelly SM, Gryczynski J, Mitchell SG, . Validity of brief screening instrument for adolescent tobacco, alcohol, and drug use. Pediatrics. 2014;133(5):819–26. PMID: 24753528. 10.1542/peds.2013-2346 24753528
- Knight J, Sherritt L, Harris S, . Validity of brief alcohol screening tests among adolescents: a comparison of the AUDIT, POSIT, CAGE, and CRAFFT. Alcohol Clin Exp Res. 2003;27(1):67–73. PMID: 12544008. 10.1097/01.ALC.0000046598.59317.3A 12544008
- Kokotailo PK, Egan J, Gangnon R, . Validity of the alcohol use disorders identification test in college students. Alcohol Clin Exp Res. 2004;28(6):914–20. PMID: 15201634. 10.1097/01.ALC.0000128239.87611.F5 15201634
- Kumar PC, Cleland CM, Gourevitch MN, . Accuracy of the Audio Computer Assisted Self Interview version of the Alcohol, Smoking and Substance Involvement Screening Test (ACASI ASSIST) for identifying unhealthy substance use and substance use disorders in primary care patients. Drug Alcohol Depend. 2016;165:38–44. PMID: 27344194. 10.1016/j.drugalcdep.2016.05.030 27344194
- Levola J, Aalto M. Screening for At-Risk Drinking in a Population Reporting Symptoms of Depression: A Validation of the AUDIT, AUDIT-C, and AUDIT-3. Alcohol Clin Exp Res. 2015;39(7):1186–92. PMID: 26058472. 10.1111/acer.12763 26058472
- Levy S, Dedeoglu F, Gaffin JM, . A Screening Tool for Assessing Alcohol Use Risk among Medically Vulnerable Youth. PloS one. 2016;11(5):e0156240. PMID: 27227975. 10.1371/journal.pone.0156240 27227975
- Lopez MB, Lichtenberger A, Conde K, . Psychometric Properties of Brief Screening Tests for Alcohol Use Disorders during Pregnancy in Argentina. Revista Brasileira de Ginecologia e Obstetricia. 2017;39(7):322–9. PMID: 28609804. 10.1055/s-0037-1603744 28609804
- McCann BS, Simpson TL, Ries R, . Reliability and validity of screening instruments for drug and alcohol abuse in adults seeking evaluation for attention-deficit/hyperactivity disorder. Am J Addict. 2000;9(1):1–9. PMID: 10914288. 10.1080/10550490050172173 10914288
- McGinnis KA, Justice AC, Kraemer KL, . Comparing alcohol screening measures among HIV-infected and -uninfected men. Alcohol Clin Exp Res. 2013;37(3):435–42. PMID: 23050632. 10.1111/j.1530-0277.2012.01937.x 23050632
- McNeely J, Strauss SM, Saitz R, . A Brief Patient Self-administered Substance Use Screening Tool for Primary Care: Two-site Validation Study of the Substance Use Brief Screen (SUBS). Am J Med. 2015;128(7):784.e9–19. PMID: 25770031. 10.1016/j.amjmed.2015.02.007 25770031
  - McNeely J, Cleland CM, Strauss SM, . Validation of Self-Administered Single-Item Screening Questions (SISQs) for Unhealthy Alcohol and Drug Use in Primary Care Patients. J Gen Intern Med. 2015;30(12):1757–64. PMID: 25986138 10.1007/s11606-015-3391-6 25986138
- McNeely J, Wu LT, Subramaniam G, . Performance of the Tobacco, Alcohol, Prescription Medication, and Other Substance Use (TAPS) Tool for Substance Use Screening in Primary Care Patients. Ann Intern Med. 2016. PMID: 27595276. 10.7326/m16-0317 27595276
- Gryczynski J, McNeely J, Wu LT, . Validation of the TAPS-1: A Four-Item Screening Tool to Identify Unhealthy Substance Use in Primary Care. J Gen Intern Med. 2017. PMID: 28550609. 10.1007/s11606-017-4079-x 28550609
- Northrup TF, Malone PS, Follingstad D, . Using item response theory to improve alcohol dependence screening for African American and White male and female college students. Addict Disord Their Treat. 2013;12(2):99–109. 10.1097/ADT.0b013e3182627431
  - Northrup TF. Effective measurement of problematic drinking for college students: Reducing differential item functioning across gender and race. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2010;70(7-B):4492. PMID: None.
- Piccinelli M, Tessari E, Bortolomasi M, . Efficacy of the alcohol use disorders identification test as a screening tool for hazardous alcohol intake and related disorders in primary care: a validity study. BMJ. 1997;314(7078):420–4. PMID: 9040389. 10.1136/bmj.314.7078.420 9040389
- Rumpf HJ, Hapke U, Meyer C, . Screening for alcohol use disorders and at-risk drinking in the general population: psychometric performance of three questionnaires. Alcohol Alcohol. 2002;37(3):261–8. PMID: 12003915.12003915
- Rumpf HJ, Wohlert T, Freyer-Adam J, . Screening questionnaires for problem drinking in adolescents: performance of AUDIT, AUDIT-C, CRAFFT and POSIT. Eur Addict Res. 2013;19(3):121–7. PMID: 23183686. 10.1159/000342331 23183686
- Santis R, Garmendia ML, Acuna G, . The Alcohol Use Disorders Identification Test (AUDIT) as a screening instrument for adolescents. Drug Alcohol Depend. 2009;103(3):155–8. PMID: 19423240. 10.1016/j.drugalcdep.2009.01.017 19423240
- Seale JP, Boltri JM, Shellenberger S, . Primary care validation of a single screening question for drinkers. J Stud Alcohol Drugs. 2006;67(5):778–84. PMID: 16847548. 10.15288/jsa.2006.67.778 16847548
  - Johnson JA, Lee A, Vinson D, . Use of AUDIT-based measures to identify unhealthy alcohol use and alcohol dependence in primary care: a validation study. Alcohol Clin Exp Res. 2013;37: Suppl 1:E253–9. PMID: 22834916. 10.1111/j.1530-0277.2012.01898.x 22834916
- Smith PC, Schmidt SM, Allensworth-Davies D, . Primary care validation of a single-question alcohol screening test.[Erratum appears in J Gen Intern Med. 2010 Apr;25(4):375]. J Gen Intern Med. 2009;24(7):783–8. PMID: 19247718. 10.1007/s11606-009-0928-6 19247718
  - Saitz R, Cheng DM, Allensworth-Davies D, . The ability of single screening questions for unhealthy alcohol and other drug use to identify substance dependence in primary care. J Stud Alcohol Drugs. 2014;75(1):153–7. PMID: 24411807. 10.15288/jsad.2014.75.153 24411807
- Volk RJ, Steinbauer JR, Cantor SB, . The Alcohol Use Disorders Identification Test (AUDIT) as a screen for at-risk drinking in primary care patients of different racial/ethnic backgrounds. Addiction. 1997;92(2):197–206. PMID: 9158231. 10.1111/j.1360-0443.1997.tb03652.x 9158231
  - Bradley KA, DeBenedetti AF, Volk RJ, . AUDIT-C as a brief screen for alcohol misuse in primary care. Alcohol Clin Exp Res. 2007;31(7):1208–17. PMID: 17451397. 10.1111/j.1530-0277.2007.00403.x 17451397
  - Frank D, DeBenedetti AF, Volk RJ, . Effectiveness of the AUDIT-C as a screening test for alcohol misuse in three race/ethnic groups. J Gen Intern Med. 2008;23(6):781–7. PMID: 18421511. 10.1007/s11606-008-0594-0 18421511

KQ4, KQ5:

- Aalto M, Saksanen R, Laine P, . Brief intervention for female heavy drinkers in routine general practice: a 3-year randomized, controlled study. Alcohol Clin Exp Res. 2000;24(11):1680–6. PMID: 11104115. 10.1111/j.1530-0277.2000.tb01969.x 11104115
  - Aalto M, Seppa K, Mattila P, . Brief intervention for male heavy drinkers in routine general practice: a three-year randomized controlled study. Alcohol Alcohol. 2001;36(3):224–30. PMID: 11373259. 10.1093/alcalc/36.3.224 11373259
- Bertholet N, Cunningham JA, Faouzi M, . Internet-based brief intervention for young men with unhealthy alcohol use: a randomized controlled trial in a general population sample. Addiction. 2015;110(11):1735–43. PMID: 26173842. 10.1111/add.13051 26173842
- Bischof G, Grothues JM, Reinhardt S, . Evaluation of a telephone-based stepped care intervention for alcohol-related disorders: a randomized controlled trial. Drug Alcohol Depend. 2008;93(3):244–51. PMID: 18054443. 10.1016/j.drugalcdep.2007.10.003 18054443
  - Grothues JM, Bischof G, Reinhardt S, . Effectiveness of brief alcohol interventions for general practice patients with problematic drinking behavior and comorbid anxiety or depressive disorders. Drug Alcohol Depend. 2008;94(1–3):214–20. PMID: 18207336. 10.1016/j.drugalcdep.2007.11.015 18207336
  - Reinhardt S, Bischof G, Grothues J, . Gender differences in the efficacy of brief interventions with a stepped care approach in general practice patients with alcohol-related disorders. Alcohol Alcohol. 2008;43(3):334–40. PMID: 18263901. 10.1093/alcalc/agn004 18263901
- Burge SK, Amodei N, Elkin B, . An evaluation of two primary care interventions for alcohol abuse among Mexican-American patients. Addiction. 1997;92(12):1705–16. PMID: 9581003. 10.1111/j.1360-0443.1997.tb02891.x 9581003
- Butler C, Simpson S, Hood K, . Training practitioners to deliver opportunistic multiple behaviour change counselling in primary care: a cluster randomised trial. BMJ. 2013;346:f1191. PMID: 23512758. 10.1136/bmj.f1191 23512758
- Carey KB, Carey MP, Maisto SA, . Brief motivational interventions for heavy college drinkers: A randomized controlled trial. J Consult Clin Psychol. 2006;74(5):943–54. PMID: 17032098. 10.1037/0022-006X.74.5.943 17032098
- Chang G, Fisher ND, Hornstein MD, . Brief intervention for women with risky drinking and medical diagnoses: a randomized controlled trial. J Subst Abuse Treat. 2011;41(2):105–14. PMID: 21489738. 10.1016/j.jsat.2011.02.011 21489738
  - Rossi BV, Chang G, Berry KF, . In vitro fertilization outcomes and alcohol consumption in at-risk drinkers: the effects of a randomized intervention. Am J Addict. 2013;22(5):481–5. PMID: 23952894. 10.1111/j.1521-0391.2013.12019.x 23952894
- Chang G, McNamara TK, Orav EJ, . Brief intervention for prenatal alcohol use: a randomized trial. Obstet Gynecol. 2005;105(5 Pt 1):991–8. PMID: 15863535. 10.1097/01.AOG.0000157109.05453.84 15863535
- Chang G, Wilkins-Haug L, Berman S, . Brief intervention for alcohol use in pregnancy: a randomized trial. Addiction. 1999;94(10):1499–508. PMID: 10790902. 10.1046/j.1360-0443.1999.941014996.x 10790902
- Collins SE, Kirouac M, Lewis MA, . Randomized controlled trial of web-based decisional balance feedback and personalized normative feedback for college drinkers. J Stud Alcohol Drugs. 2014;75(6):982–92. PMID: 25343656. 10.15288/jsad.2014.75.982 25343656
- Crawford MJ, Sanatinia R, Barrett B, . The clinical effectiveness and cost-effectiveness of brief intervention for excessive alcohol consumption among people attending sexual health clinics: a randomised controlled trial (SHEAR). Health Technol Assess. 2014;18(30):1–48. PMID: 24813652. 10.3310/hta18300 24813652
  - Crawford MJ, Sanatinia R, Barrett B, . The clinical and cost-effectiveness of brief advice for excessive alcohol consumption among people attending sexual health clinics: a randomised controlled trial. Sex Transm Infect. 2015;91(1):37–43. PMID: 24936090. 10.1136/sextrans-2014-051561 24936090
- Cunningham JA, Neighbors C, Wild C, . Ultra-brief intervention for problem drinkers: results from a randomized controlled trial. PloS one. 2012;7(10):e48003. PMID: 23110157. 10.1371/journal.pone.0048003 23110157
- Curry SJ, Ludman EJ, Grothaus LC, . A randomized trial of a brief primary-care-based intervention for reducing at-risk drinking practices. Health Psychol. 2003;22(2):156–65. PMID: 12683736. 10.1037/0278-6133.22.2.156 12683736
- Daeppen JB, Bertholet N, Gaume J, . Efficacy of brief motivational intervention in reducing binge drinking in young men: A randomized controlled trial. Drug Alcohol Depend. 2011;113(1):69–75. PMID: 20729010. 10.1016/j.drugalcdep.2010.07.009 20729010
- Drummond C, Coulton S, James D, . Effectiveness and cost-effectiveness of a stepped care intervention for alcohol use disorders in primary care: pilot study. Br J Psychiatry. 2009;195(5):448–56. PMID: 19880936. 10.1192/bjp.bp.108.056697 19880936
- Emmen MJ, Schippers GM, Wollersheim H, . Adding psychologist’s intervention to physicians’ advice to problem drinkers in the outpatient clinic. Alcohol Alcohol. 2005;40(3):219–26. PMID: 15699056. 10.1093/alcalc/agh137 15699056
- Ettner SL, Xu H, Duru OK, . The effect of an educational intervention on alcohol consumption, at-risk drinking, and health care utilization in older adults: the Project SHARE study. J Stud Alcohol Drugs. 2014;75(3):447–57. PMID: 24766757. 10.15288/jsad.2014.75.447 24766757
- Fleming MF, Balousek SL, Grossberg PM, . Brief physician advice for heavy drinking college students: a randomized controlled trial in college health clinics. J Stud Alcohol Drugs. 2010;71(1):23–31. PMID: 20105410. 10.15288/jsad.2010.71.23 20105410
  - Fleming MF, Mundt MP, French MT, . Brief physician advice for problem drinkers: long-term efficacy and benefit-cost analysis. Alcohol Clin Exp Res. 2002;26(1):36–43. PMID: 11821652. 10.1111/j.1530-0277.2002.tb02429.x 11821652
  - Grossberg PM, Brown DD, Fleming MF. Brief physician advice for high-risk drinking among young adults. Ann Fam Med. 2004;2(5):474–80. PMID: 15506584. 10.1370/afm.122 15506584
  - Manwell LB, Fleming MF, Mundt MP, . Treatment of problem alcohol use in women of childbearing age: results of a brief intervention trial. Alcohol Clin Exp Res. 2000;24(10):1517–24. PMID: 11045860. 10.1111/j.1530-0277.2000.tb04570.x 11045860
- Fleming MF, Barry KL, Manwell LB, . Brief physician advice for problem alcohol drinkers. A randomized controlled trial in community-based primary care practices. JAMA. 1997;277(13):1039–45. PMID: 9091691. 10.1001/jama.1997.03540370029032 9091691
- Fleming MF, Lund MR, Wilton G, . The Healthy Moms Study: the efficacy of brief alcohol intervention in postpartum women. Alcohol Clin Exp Res. 2008;32(9):1600–6. PMID: 18627361. 10.1111/j.1530-0277.2008.00738.x 18627361
  - Wilton G, Moberg DP, Fleming MF. The effect of brief alcohol intervention on postpartum depression. MCN Am J Matern Child Nurs. 2009;34(5):297–302. PMID: 19713798. 10.1097/01.NMC.0000360422.06486.c4 19713798
- Fleming MF, Manwell LB, Barry KL, . Brief physician advice for alcohol problems in older adults: a randomized community-based trial. J Fam Pract. 1999;48(5):378–84. PMID: 10334615.10334615
  - Mundt MP, French MT, Roebuck M, . Brief physician advice for problem drinking among older adults: an economic analysis of costs and benefits. J Stud Alcohol. 2005;66(3):389–94. PMID: 16047528. 10.15288/jsa.2005.66.389 16047528
- Hansen AB, Becker U, Nielsen AS, . Internet-based brief personalized feedback intervention in a non-treatment-seeking population of adult heavy drinkers: a randomized controlled trial. J Med Internet Res. 2012;14(4):e98. PMID: 22846542. 10.2196/jmir.1883 22846542
- Haug S, Paz Castro R, Kowatsch T, . Efficacy of a Web- and Text Messaging-Based Intervention to Reduce Problem Drinking in Adolescents: Results of a Cluster-Randomized Controlled Trial. J Consult Clin Psychol. 2016. PMID: 27606700. 10.1037/ccp0000138 27606700
  - Paz CR, Haug S, Kowatsch T, . Moderators of outcome in a technology-based intervention to prevent and reduce problem drinking among adolescents. Addict Behav. 2017;72:64–71. PMID: 28371696. 10.1016/j.addbeh.2017.03.013 28371696
- Heather N, Campion PD, Neville RG, . Evaluation of a controlled drinking minimal intervention for problem drinkers in general practice (the DRAMS scheme). J R Coll Gen Pract. 1987;37(301):358–63. PMID: 3448228.3448228
- Helstrom AW, Ingram E, Wang W, . Treating heavy drinking in primary care practices: Evaluation of a telephone-based intervention program. Addict Disord Their Treat. 2014;13(3):101–9. PMID: None. 10.1097/ADT.0b013e31827e206c
- Hilbink M, Voerman G, van Beurden I, . A randomized controlled trial of a tailored primary care program to reverse excessive alcohol consumption. J Am Board Fam Med. 2012;25(5):712–22. PMID: 22956707. 10.3122/jabfm.2012.05.120070 22956707
- Johnsson KO, Berglund M. Comparison between a cognitive behavioural alcohol programme and post-mailed minimal intervention in high-risk drinking university freshmen: results from a randomized controlled trial. Alcohol Alcohol. 2006;41(2):174–80. PMID: 16322100. 10.1093/alcalc/agh243 16322100
- Kaner E, Bland M, Cassidy P, . Effectiveness of screening and brief alcohol intervention in primary care (SIPS trial): pragmatic cluster randomised controlled trial. BMJ. 2013;346:e8501. PMID: 23303891. 10.1136/bmj.e8501 23303891
  - Coulton S, Dale V, Deluca P, . Screening for At-Risk Alcohol Consumption in Primary Care: A Randomized Evaluation of Screening Approaches. Alcohol & Alcoholism. 2017;52(3):312–7. PMID: 28371897. 10.1093/alcalc/agx017 28371897
  - Kaner E, Bland M, Cassidy P, . Screening and brief interventions for hazardous and harmful alcohol use in primary care: a cluster randomised controlled trial protocol. BMC Public Health. 2009;9:287. PMID: 19664255. 10.1186/1471-2458-9-287 19664255
- Kypri K, Hallett J, Howat P, . Randomized controlled trial of proactive web-based alcohol screening and brief intervention for university students. Arch Intern Med. 2009;169(16):1508–14. PMID: 19752409. 10.1001/archinternmed.2009.249 19752409
- Kypri K, Langley JD, Saunders JB, . Randomized controlled trial of web-based alcohol screening and brief intervention in primary care. Arch Intern Med. 2008;168(5):530–6. PMID: 18332300. 10.1001/archinternmed.2007.109 18332300
  - Kypri K, Langley JD, Saunders J, . Assessment may conceal therapeutic benefit: findings from a randomized controlled trial for hazardous drinking. Addiction. 2007;102(1):62–70. PMID: 17207124. 10.1111/j.1360-0443.2006.01632.x 17207124
- Kypri K, Saunders JB, Williams SM, . Web-based screening and brief intervention for hazardous drinking: a double-blind randomized controlled trial. Addiction. 2004;99(11):1410–7. PMID: 15500594. 10.1111/j.1360-0443.2004.00847.x 15500594
- LaBrie JW, Huchting KK, Lac A, . Preventing risky drinking in first-year college women: further validation of a female-specific motivational-enhancement group intervention. J Stud Alcohol Drugs Suppl. 2009(16):77–85. PMID: 19538915. 10.15288/jsads.2009.s16.77 19538915
- LaBrie JW, Lewis MA, Atkins DC, . RCT of web-based personalized normative feedback for college drinking prevention: are typical student norms good enough? J Consult Clin Psychol. 2013;81(6):1074–86. PMID: 23937346. 10.1037/a0034087 23937346
- Larimer ME, Lee CM, Kilmer JR, . Personalized mailed feedback for college drinking prevention: a randomized clinical trial. J Consult Clin Psychol. 2007;75(2):285–93. PMID: 17469886. 10.1037/0022-006X.75.2.285 17469886
- Leeman RF, DeMartini KS, Gueorguieva R, . Randomized Controlled Trial of a Very Brief, Multicomponent Web-Based Alcohol Intervention for Undergraduates With a Focus on Protective Behavioral Strategies. J Consult Clin Psychol. 2016. PMID: 27599223. 10.1037/ccp0000132 27599223
- Lewis MA, Patrick ME, Litt DM, . Randomized controlled trial of a web-delivered personalized normative feedback intervention to reduce alcohol-related risky sexual behavior among college students. J Consult Clin Psychol. 2014;82(3):429–40. PMID: 24491076. 10.1037/a0035550 24491076
- Maisto SA, Conigliaro J, McNeil M, . Effects of two types of brief intervention and readiness to change on alcohol use in hazardous drinkers. J Stud Alcohol. 2001;62(5):605–14. PMID: 11702799. 10.15288/jsa.2001.62.605 11702799
  - Gordon AJ, Conigliaro J, Maisto SA, . Comparison of consumption effects of brief interventions for hazardous drinking elderly. Subst Use Misuse. 2003;38(8):1017–35. PMID: 12901447. 10.1081/JA-120017649 12901447
  - Maisto SA, Conigliaro J, McNeil M, . The relationship between eligibility criteria for participation in alcohol brief intervention trials and other alcohol and health-related variables. Am J Addict. 2001;10(3):218–31. PMID: 11579620. 10.1080/105504901750532102 11579620
- Marlatt GA, Baer JS, Kivlahan DR, . Screening and brief intervention for high-risk college student drinkers: results from a 2-year follow-up assessment. J Consult Clin Psychol. 1998;66(4):604–15. PMID: 9735576. 10.1037/0022-006X.66.4.604 9735576
  - Baer JS, Kivlahan DR, Blume AW, . Brief intervention for heavy-drinking college students: 4-year follow-up and natural history. Am J Public Health. 2001;91(8):1310–6. PMID: 11499124.11499124
  - Roberts LJ, Neal DJ, Kivlahan DR, . Individual drinking changes following a brief intervention among college students: clinical significance in an indicated preventive context. J Consult Clin Psychol. 2000;68(3):500–5. PMID: 10883566. 10.1037/0022-006X.68.3.500 10883566
- Martens MP, Kilmer JR, Beck NC, . The efficacy of a targeted personalized drinking feedback intervention among intercollegiate athletes: a randomized controlled trial. Psychol Addict Behav. 2010;24(4):660–9. PMID: 20822189. 10.1037/a0020299 20822189
- Mason M, Light J, Campbell L, . Peer Network Counseling with Urban Adolescents: A Randomized Controlled Trial with Moderate Substance Users. J Subst Abuse Treat. 2015;58:16–24. PMID: 26234955. 10.1016/j.jsat.2015.06.013 26234955
- Montag AC, Brodine SK, Alcaraz JE, . Preventing alcohol-exposed pregnancy among an American Indian/Alaska Native population: effect of a screening, brief intervention, and referral to treatment intervention. Alcohol Clin Exp Res. 2015;39(1):126–35. PMID: 25623412. 10.1111/acer.12607 25623412
  - Montag AC, Brodine SK, Alcaraz JE, . Effect of Depression on Risky Drinking and Response to a Screening, Brief Intervention, and Referral to Treatment Intervention. Am J Public Health. 2015;105(8):1572–6. PMID: 26066915. 10.2105/AJPH.2015.302688 26066915
- Moore A, Blow F, Hoffing M, . Primary care-based intervention to reduce at-risk drinking in older adults: a randomized controlled trial. Addiction. 2010;106(1):111–20. PMID: 21143686. 10.1111/j.1360-0443.2010.03229.x.21143686
  - Lin J, Karno M, Tang L, . Do health educator telephone calls reduce at-risk drinking among older adults in primary care? J Gen Intern Med. 2010;25(4):334–9. PMID: 20101471. 10.1007/s11606-009-1223-2 20101471
- Neighbors C, Larimer ME, Lewis MA. Targeting misperceptions of descriptive drinking norms: efficacy of a computer-delivered personalized normative feedback intervention. J Consult Clin Psychol. 2004;72(3):434–47. PMID: 15279527. 10.1037/0022-006X.72.3.434 15279527
  - Young CM, Neighbors C, Dibello AM, . Coping motives moderate efficacy of personalized normative feedback among heavy drinking U.S. college students. J Stud Alcohol Drugs. 2016;77(3):495–9. PMID: 27172582. 10.15288/jsad.2016.77.495 27172582
- Neighbors C, Lewis MA, Atkins DC, . Efficacy of web-based personalized normative feedback: a two-year randomized controlled trial. J Consult Clin Psychol. 2010;78(6):898–911. PMID: 20873892. 10.1037/a0020766 20873892
- Neighbors C, Lewis MA, LaBrie J, . A multisite randomized trial of normative feedback for heavy drinking: Social comparison versus social comparison plus correction of normative misperceptions. J Consult Clin Psychol. 2016;84(3):238–47. PMID: 26727407. 10.1037/ccp0000067 26727407
- Ockene JK, Adams A, Hurley TG, . Brief physician- and nurse practitioner-delivered counseling for high-risk drinkers: does it work? Arch Intern Med. 1999;159(18):2198–205. PMID: 10527297. 10.1001/archinte.159.18.2198 10527297
  - Ockene JK, Reed GW, Reiff-Hekking S. Brief patient-centered clinician-delivered counseling for high-risk drinking: 4-year results. Ann Behav Med. 2009;37(3):335–42. PMID: 19707840. 10.1007/s12160-009-9108-5 19707840
  - Reiff-Hekking S, Ockene JK, Hurley TG, . Brief physician and nurse practitioner-delivered counseling for high-risk drinking. Results at 12-month follow-up. J Gen Intern Med. 2005;20(1):7–13. PMID: 15693921. 10.1111/j.1525-1497.2005.21240.x 15693921
- O’Connor MJ, Whaley SE. Brief intervention for alcohol use by pregnant women. Am J Public Health. 2007;97(2):252–8. PMID: 17194863. 10.2105/AJPH.2005.077222 17194863
- Ondersma SJ, Beatty JR, Svikis DS, . Computer-Delivered Screening and Brief Intervention for Alcohol Use in Pregnancy: A Pilot Randomized Trial. Alcohol Clin Exp Res. 2015;39(7):1219–26. PMID: 26010235. 10.1111/acer.12747 26010235
- Ondersma SJ, Svikis DS, Thacker LR, . A randomised trial of a computer-delivered screening and brief intervention for postpartum alcohol use. Drug Alcohol Rev. 2016. PMID: 27004474. 10.1111/dar.12389 27004474
- Osterman RL, Carle AC, Ammerman RT, . Single-session motivational intervention to decrease alcohol use during pregnancy. J Subst Abuse Treat. 2014;47(1):10–9. PMID: 24637202. 10.1016/j.jsat.2014.01.009 24637202
- Reynolds KD, Coombs DW, Lowe JB, . Evaluation of a self-help program to reduce alcohol consumption among pregnant women. Int J Addict. 1995;30(4):427–43. PMID: 7607777. 10.3109/10826089509048735 7607777
- Richmond R, Heather N, Wodak A, . Controlled evaluation of a general practice-based brief intervention for excessive drinking. Addiction. 1995;90(1):119–32. PMID: 7888970. 10.1046/j.1360-0443.1995.90111915.x 7888970
- Rose GL, Badger GJ, Skelly JM, . A Randomized Controlled Trial of Brief Intervention by Interactive Voice Response. Alcohol Alcohol. 2017;52(3):335–43. PMID: 28069598. 10.1093/alcalc/agw102 28069598
- Rubio DM, Day NL, Conigliaro J, . Brief motivational enhancement intervention to prevent or reduce postpartum alcohol use: a single-blinded, randomized controlled effectiveness trial. J Subst Abuse Treat. 2014;46(3):382–9. PMID: 24315218. 10.1016/j.jsat.2013.10.009 24315218
- Rubio G, Jimenez-Arriero MA, Martinez I, . Efficacy of physician-delivered brief counseling intervention for binge drinkers. Am J Med. 2010;123(1):72–8. PMID: 20102995. 10.1016/j.amjmed.2009.08.012 20102995
- Saitz R, Horton NJ, Sullivan LM, . Addressing alcohol problems in primary care: a cluster randomized, controlled trial of a systems intervention. The screening and intervention in primary care (SIP) study. Ann Intern Med. 2003;138(5):372–82. PMID: 12614089. 10.7326/0003-4819-138-5-200303040-00006 12614089
- Schaus JF, Sole ML, McCoy TP, . Alcohol screening and brief intervention in a college student health center: a randomized controlled trial. J Stud Alcohol Drugs Suppl. 2009(16):131–41. PMID: 19538921. 10.15288/jsads.2009.s16.131 19538921
- Schulz DN, Candel MJ, Kremers SP, . Effects of a Web-based tailored intervention to reduce alcohol consumption in adults: randomized controlled trial. Journal of medical Internet research. 2013;15(9):e206. PMID: 24045005. 10.2196/jmir.2568 24045005
- Scott E, Anderson P. Randomized controlled trial of general practitioner intervention in women with excessive alcohol consumption. Drug Alcohol Rev. 1990;10(4):313–21. PMID: 16818295. 10.1080/09595239100185371 16818295
  - Anderson P, Scott E. The effect of general practitioners’ advice to heavy drinking men. Br J Addict. 1992;87(6):891–900. PMID: 1525531. 10.1111/j.1360-0443.1992.tb01984.x 1525531
- Senft RA, Polen MR, Freeborn DK, . Brief intervention in a primary care setting for hazardous drinkers. Am J Prev Med. 1997;13(6):464–70. PMID: 9415794.9415794
  - Freeborn DK, Polen MR, Hollis JF, . Screening and brief intervention for hazardous drinking in an HMO: effects on medical care utilization. J Behav Health Serv Res. 2000;27(4):446–53. PMID: 11070638.11070638
- Turrisi R, Larimer ME, Mallett KA, . A randomized clinical trial evaluating a combined alcohol intervention for high-risk college students. J Stud Alcohol Drugs. 2009;70(4):555–67. PMID: 19515296.19515296
  - Cleveland MJ, Lanza ST, Ray AE, . Transitions in first-year college student drinking behaviors: does pre-college drinking moderate the effects of parent- and peer-based intervention components? Psychol Addict Behav. 2012;26(3):440–50. PMID: 22061340. 10.1037/a0026130 22061340
  - Grossbard JR, Mastroleo NR, Kilmer JR, . Substance use patterns among first-year college students: secondary effects of a combined alcohol intervention. J Subst Abuse Treat. 2010;39(4):384–90. PMID: 20817383. 10.1016/j.jsat.2010.07.001 20817383
- Tzilos GK, Sokol RJ, Ondersma SJ. A randomized phase I trial of a brief computer-delivered intervention for alcohol use during pregnancy. Journal of women’s health. 2011;20(10):1517–24. PMID: 21823917. 10.1089/jwh.2011.2732 21823917
- Upshur C, Weinreb L, Bharel M, . A randomized control trial of a chronic care intervention for homeless women with alcohol use problems. J Subst Abuse Treat. 2015;51:19–29. PMID: 25488504. 10.1016/j.jsat.2014.11.001 25488504
- van der Wulp NY, Hoving C, Eijmael K, . Reducing alcohol use during pregnancy via health counseling by midwives and internet-based computer-tailored feedback: a cluster randomized trial. J Med Internet Res. 2014;16(12):e274. PMID: 25486675. 10.2196/jmir.3493 25486675
- Voogt CV, Kuntsche E, Kleinjan M, . The effect of the ‘What Do You Drink’ web-based brief alcohol intervention on self-efficacy to better understand changes in alcohol use over time: randomized controlled trial using ecological momentary assessment. Drug Alcohol Depend. 2014;138:89–97. PMID: 24613632. 10.1016/j.drugalcdep.2014.02.009 24613632
  - Voogt CV, Poelen EA, Kleinjan M, . Targeting young drinkers online: the effectiveness of a web-based brief alcohol intervention in reducing heavy drinking among college students: study protocol of a two-arm parallel group randomized controlled trial. BMC Public Health. 2011;11:231. PMID: 21492412. 10.1186/1471-2458-11-231 21492412
  - Voogt C, Poelen E, Kleinjan M, . The effectiveness of the ‘what do you drink’ web-based brief alcohol intervention in reducing heavy drinking among students: a two-arm parallel group randomized controlled trial. Alcohol Alcohol. 2013;48(3):312–21. PMID: 23303466. 10.1093/alcalc/ags133 23303466
- Wallace P, Cutler S, Haines A. Randomised controlled trial of general practitioner intervention in patients with excessive alcohol consumption. BMJ. 1988;297(6649):663–8. PMID: 3052668.3052668
- Watkins KE, Ober AJ, Lamp K, . Collaborative Care for Opioid and Alcohol Use Disorders in Primary Care: The SUMMIT Randomized Clinical Trial. JAMA Internal Medicine. 2017;177(10):1480–8. PMID: 28846769. 10.1001/jamainternmed.2017.3947 28846769
- Watson JM, Crosby H, Dale VM, . AESOPS: a randomised controlled trial of the clinical effectiveness and cost-effectiveness of opportunistic screening and stepped care interventions for older hazardous alcohol users in primary care. Health Technol Assess. 2013;17(25):1–158. PMID: 23796191. 10.3310/hta17250 23796191
  - Coulton S, Bland M, Crosby H, . Effectiveness and Cost-effectiveness of Opportunistic Screening and Stepped-care Interventions for Older Alcohol Users in Primary Care. Alcohol Alcohol. 2017:1–10. PMID: 29016980. 10.1093/alcalc/agx065 27651282
- Wilson GB, Wray C, McGovern R, . Intervention to reduce excessive alcohol consumption and improve comorbidity outcomes in hypertensive or depressed primary care patients: two parallel cluster randomized feasibility trials. Trials. 2014;15:235. PMID: 24947447. 10.1186/1745-6215-15-235 24947447