# Appendix D Recommendations of Others

Organization | Year | Recommendation
American Academy of Pediatrics (AAP)^81,^ ^341,^ ^342^ | 2016 | - Pediatricians should increase their capacity in substance use detection, assessment, and intervention.; - Pediatricians should become familiar with adolescent SBIRT practices and their potential to be incorporated into universal screening and comprehensive care of adolescents in the medical home.
American Academy of Pediatrics (AAP)^81,^ ^341,^ ^342^ | 2011 (Reaffirmed 2014) | - Providers should regularly screen all adolescent patients for alcohol use with validated screening tools and respond to screening results with the appropriate brief intervention.
American Academy of Pediatrics (AAP)^81,^ ^341,^ ^342^ | 2001 | - Pediatricians should strongly advise against the use of alcohol and should assess their patients’ current use of alcohol using a nonjudgmental approach.; - Pediatricians should discuss the hazards of alcohol and other drug use with their patients as a routine part of risk behavior assessment.; - Pediatricians should be able recognize early signs and symptoms of alcohol abuse so they can properly evaluate, manage, and refer patients for further assessment and treatment as indicated.
U.S. Department of Veterans Affairs (VA)^76^ | 2015 | - For patients in general medical and mental health care settings, screening for unhealthy alcohol annually using the three-item Alcohol Use Disorders Identification Test-Consumption (AUDIT-C) or Single Item Alcohol Screening Questionnaire (SASQ) is recommended.; - For patients without documented alcohol use disorder who screen positive for unhealthy alcohol use, physicians should provide a single, initial brief intervention regarding alcohol-related risks and advice to abstain or drink within nationally established age and gender-specific limits for daily and weekly consumption.; - For patients with a diagnosis of a substance use disorder, physicians should offer referral for specialty substance use disorder care based on willingness to engage in specialty treatment.
Surgeon General of the United States^77^ | 2014 | - Clinicians should identify alcohol abuse disorders early and provide brief intervention, referral and treatment.; - Clinicians should identify and screen patients for excessive drinking using a Screening, Brief Intervention, and Referral to Treatment (SBIRT) approach, implement provider reminder systems for SBIRT (e.g., electronic medical record clinical reminders) and evaluate the effectiveness of alternative methods for providing SBIRT (e.g., by phone or via the internet).
American Congress of Obstetricians and Gynecologists (ACOG)^82^ | 2011 (Reaffirmed 2014) | - All women should be screened for alcohol use both before pregnancy and in their first trimester of pregnancy, using validated tools such as TACE.; - If unhealthy alcohol use is identified, brief counseling should be provided with referral to treatment if deemed necessary.
National Institute for Health and Clinical Excellence (NICE)^343^ | 2011 | - Health and social care staff should receive alcohol awareness training that promotes respectful, non-judgmental care of people who misuse alcohol.; - Health and social care staff opportunistically carry out screening and brief interventions for hazardous and harmful drinking as an integral part of practice.; - Adults who misuse alcohol are offered evidence-based psychological interventions, and those with alcohol dependence that is moderate or severe can in addition access relapse prevention medication in accordance with NICE guidance.; - Children and young people accessing specialist services for alcohol use are offered individual cognitive behavioural therapy, or if they have significant comorbidities or limited social support, a multicomponent program of care including family or systems therapy.
National Institute on Alcohol Abuse and Alcoholism (NIAAA)^78^ | 2007 | - Physicians should screen adult patients for at-risk drinking and provide brief counselling for at-risk drinkers.; - Pharmacotherapy with medical management is recommended for treatment of alcohol dependence.; - Patients with alcohol dependence should be referred for specialized alcohol counselling.; - Patients with chronic alcohol dependence and serious medical complications should receive ongoing care management.
American Society of Addiction Medicine (ASAM)^79^ | 1997 | - Primary care providers should routinely screen patients about alcohol use problems, screen for risk factors for development of alcohol dependence, and provide appropriate interventions and services.

Abbreviations: AAP = American Academy of Pediatrics; ACOG = American College of Obstetricians and Gynecologists; ASAM = American Society of Addiction Medicine; NIAAA = National Institute on Alcohol Abuse and Alcoholism; NICE= National Institute for Health and Clinical Excellence; SBIRT = Brief Intervention and Referral to Treatment; TACE = Tolerance, Annoy, Cut down, Eye-opener; VA = U.S. Department of Veterans Affairs; WHO = World Health Organization.