# Appendix C Screening Instruments to Identify Unhealthy Alcohol Use*

Instrument name | Description | No. items/questions Time to administer | Scoring notes
ARPS | Includes items in the following: domains:; - presence of medical and psychiatric conditions (14 items);; - symptoms of disease (12 items);; - smoking behavior (1 item);; - medication use (17 items),; - physical function and health status (6 items);; - quantity and frequency of alcohol use (2 items);; - episodic heavy drinking (2 items);; - symptoms of alcohol abuse and dependence (4 items);; - driving after drinking (1 item), and; - gender (1 item). | 60 16 min | Developed for older adults; Complex scoring algorithm; Classifies as harmful, hazardous, or nonhazardous
ASSIST | Instrument is a brief interview about alcohol, tobacco products, and other drugs; alcoholic beverages (beer, wine, spirits, etc.) are a subset of each questionnaire item, which each lists a series of substances for potential abuse screening.; - Lifetime use (Response Choices: No=0; Yes=3); - Use in past 3 months (Response Choices: Never=0; Once or Twice=2; Monthly=3; Weekly=4; Daily or Almost Daily=6); - During the past 3 months, strong desire or urge to use (Response Choices: Never=0; Once or Twice=3; Monthly=4; Weekly=5; Daily or Almost Daily=6); - During the past 3 months, how often use led to health, social, legal or financial problems (Response Choices: Never=0; Once or Twice=4; Monthly=5; Weekly=6; Daily or Almost Daily=7); - During the past 3 months, how often failed to do what was normally expected because of use (Response Choices: Never=0; Once or Twice=5; Monthly=6; Weekly=7; Daily or Almost Daily=8); - Friend or relative or anyone else expressed concern about use (Response choices: No, Never=0; Yes, in the past 3 months=6; Yes, but not in the past 3 months=3); - Ever tried and failed to control, cut down or stop using (Response choices: No, Never=0; Yes, in the past 3 months=6; Yes, but not in the past 3 months=3); - Ever used any drug by injection Response choices: No, Never=0; Yes, in the past 3 months=2; Yes, but not in the past 3 months=1) | 8 2-4 min | Add up the scores received for questions 2 through 7 inclusive. Does not include the results from either Q1 or Q8. Score 0-10: no intervention; risk level low Score 11-26: receive brief intervention; risk level moderate Score 27+ more intensive treatment; risk level high. Further assessment and more intensive treatment may be provided by the health professional(s) within primary care setting, or, by a specialist drug and alcohol treatment service when available.
AUDIT | 1. How often do you have a drink containing alcohol?; 0 NEVER; 1 MONTHLY OR LESS; 2 TWO TO FOUR TIMES A MONTH; 3 TWO TO THREE TIMES A WEEK; 4 FOUR OR MORE TIMES A WEEK; 2. How many drinks containing alcohol do you have on a typical day when you are drinking?; 0 1 OR 2; 1 3 or 4; 2 5 OR 6; 3 7 TO 9; 4 10 OR MORE; 3. How often do you have six^*^ or more drinks on one occasion?; 0 NEVER; 1 LESS THAN MONTHLY; 2 MONTHLY; 3 WEEKLY; 4 DAILY OR ALMOST DAILY; 4. How often during the last year have you found that you were not able to stop drinking once you had started? (same options as #3); 5. How often during the last year have you failed to do what was normally expected from you because of drinking? (same options as #3); 6. How often during the last year have you needed a first drink in the morning to get yourself going after a heavy drinking session? (same options as #3); 7. How often during the last year have you had a feeling of guilt or remorse after drinking? (same options as #3); 8. How often during the last year have you been unable to remember what happened the night before because you have been drinking? (same options as #3); 9. Have you or someone else been injured as a result of your drinking?; 0 NO; 1 YES, BUT NOT IN THE LAST YEAR; 2 YES, DURING THE LAST YEAR; 10. Has a relative or friend or a doctor or other health worker been concerned about your drinking or suggested you cut down? (same options as #9); * The U.S. version asks about five or more drinks, reflecting standard drink sizes in the United States. | 10 2-5 min | Scoring: ≥8 considered a positive screen for hazardous or harmful drinking. [underlined: In general:] Scores between 8 and 15 are most appropriate for simple advice focused on the reduction of hazardous drinking; Scores between 16 and 19 suggest brief counseling and continued monitoring; Scores of 20 and above clearly warrant further diagnostic evaluation for alcohol dependence.
USAUDIT | 1. How often do you have a drink containing alcohol?; 0 Never; 1 Less than monthly; 2 Monthly; 3 Weekly; 4 2-3 times a week; 5 4-6 times a week; 6 Daily; 2. How many drinks containing alcohol do you have on a typical day you are drinking?; 0 1 drink; 1 2 drinks; 2 3 drinks; 3 4 drinks; 4 5-6 drinks; 5 7-9 drinks; 6 10 or more drinks; 3. How often do you have X (5 for men; 4 for women & men over age 65) or more drinks on one occasion? (same options as #1); 4. How often during the last year have you found that you were not able to stop drinking once you had started?; 0 Never; 1 Less than monthly; 2 Monthly; 3 Weekly; 4 Daily or almost daily; 5. How often during the past year have you failed to do what was expected of you because of drinking? (same options as #4); 6. How often during the past year have you needed a drink first thing in the morning to get yourself going after a heavy drinking session? (same options as #4); 7. How often during the past year have you had a feeling of guilt or remorse after drinking? (same options as #4); 8. How often during the past year have you been unable to remember what happened the night before because you had been drinking? (same options as #4); 9. Have you or someone else been injured because of your drinking?; 0 No; 2 Yes, but not in the past year; 4 Yes, during the past year; 10. Has a relative, friend, doctor, or other health care worker been concerned about your drinking and suggested you cut down? (same options as #9) | 10 2-5 min | Scores of 7 for women (and men ages 66 and older) and 8 for men ages 65 and younger represent the thresholds beyond which drinking begins to entail health risks as endorsed by NIAAA. A score of 1 or more by pregnant women are grounds for discussing health risks. [underlined: In general:] Scores between 7/8-15 (M/F) are most appropriate for feedback and brief intervention; Scores between 16-24 are most appropriate for feedback, monitoring, and brief outpatient treatment; Scores 25 or higher warrant referral to evaluation and treatment.
AUDIT-C | 1. How often do you have a drink containing alcohol?; 0 Never; 1 Monthly or less; 2 Two to four times a month; 3 Two to three times a week; 4 Four or more times a week; 2. How many drinks containing alcohol do you have on a typical day when you are drinking?; 0 1 or 2; 1 3 or 4; 2 5 or 6; 3 7 to 9; 4 10 or more; 3. How often do you have six^*^ or more drinks on one occasion?; 0 Never; 1 Less than monthly; 2 Monthly; 3 Weekly; 4 Daily or almost daily | 3 1-2 min | In men, ≥4 points is considered positive for alcohol misuse; in women, ≥3 points is considered positive.
USAUDIT-C | 1. How often do you have a drink containing alcohol?; 0 Never; 1 Less than monthly; 2 Monthly; 3 Weekly; 4 2-3 times a week; 5 4-6 times a week; 6 Daily; 2. How many drinks containing alcohol do you have on a typical day you are drinking?; 0 1 drink; 1 2 drinks; 2 3 drinks; 3 4 drinks; 4 5-6 drinks; 5 7-9 drinks; 6 10 or more drinks; 3. How often do you have X (5 for men; 4 for women and men over age 65) or more drinks on one occasion?; 0 Never; 1 Less than monthly; 2 Monthly; 3 Weekly; 4 2-3 times a week; 5 4-6 times a week; 6 Daily | 3 1-2 min | A total of 7 or more for women and men over age 65, and 8 or more for younger males is a positive risk indicator.
CAGE | - C: have you ever felt you should cut down on your drinking?; - A: have people annoyed you by criticizing your drinking?; - G: have you ever felt bad or guilty about your drinking?; - E: eye-opener: have you ever had a drink first thing in the morning to steady your nerves or to get rid of a hangover? | 4 1 min | Score 1 point for each ‘yes’ response; range 0–4. Positive score ≥2.
CARET | 1. How often do you drink and how many drinks do you consume?; 2. Have you driven within 2 hours of drinking ≥ 3 drinks?; 3. Have people been concerned about your alcohol use in the last 12 months?; 4. Have people been concerned about your alcohol use more than 12 months ago?; 5. Are you currently taking medications that may cause bleeding, dizziness, or sedation at least 3-4 times per week?; 6. Are you currently taking medications used for gastrointestinal reflux, ulcer disease, depression or hypertension at least 3-4 times per week?; 7. In the past 12 months have you been diagnosed with liver disease, pancreatitis, gout, or depression?; 8. In the past 12 months have you been diagnosed with high blood pressure or diabetes?; 9. Do you sometimes have problems with sleeping, falling, memory, heartburn, stomach pain, nausea, vomiting, or feeling sad/blue?; 10. Have you often had problems with sleeping, falling, memory, heartburn, stomach pain, nausea, vomiting, or feeling sad/blue? | 10 2 min | Uses a complex algorithm to identify patients deemed “at risk”
LAST | 1. Are you always able to stop drinking when you want to?; 2. Have you ever felt you should cut down on your drinking?; 3. Have you ever felt bad or guilty about your drinking?; 4. Does your wife, husband, a parent, or other near relative ever worry or complain about your drinking?; 5. Have you ever gotten into trouble at work because of drinking?; 6. Have you ever been told you have liver trouble? Cirrhosis?; 7. Have you ever been in a hospital because of drinking? | 7 1-2 mins | Score 1 point for answer of “no” on question 1; score 1 point for each ‘yes on questions 2-7.’ Two or more points are indicative of alcohol dependence or abuse
MAST^†^ | All items are yes/no questions; 1. Do you feel you are a normal drinker? (“normal" - drink as much or less than most other people)?; 2. Have you ever awakened the morning after some drinking the night before and found that you could not remember a part of the evening?; 3. Does any near relative or close friend ever worry or complain about your drinking?; 4. Can you stop drinking without difficulty after one or two drinks?; 5. Do you ever feel guilty about your drinking?; 6. Have you ever attended a meeting of Alcoholics Anonymous (AA)?; 7. Have you ever gotten into physical fights when drinking?; 8. Has drinking ever created problems between you and a near relative or close friend?; 9. Has any family member or close friend gone to anyone for help about your drinking?; 10. Have you ever lost friends because of your drinking?; 11. Have you ever gotten into trouble at work because of drinking?; 12. Have you ever lost a job because of drinking?; 13. Have you ever neglected your obligations, your family, or your work for two or more days in a row because you were drinking?; 14. Do you drink before noon fairly often?; 15. Have you ever been told you have liver trouble such as cirrhosis?; 16. After heavy drinking have you ever had delirium tremens (D.T.’s), severe shaking, visual or auditory (hearing) hallucinations?; 17. Have you ever gone to anyone for help about your drinking?; 18. Have you ever been hospitalized because of drinking?; 19. Has your drinking ever resulted in your being hospitalized in a psychiatric ward?; 20. Have you ever gone to any doctor, social worker, clergyman or mental health clinic for help with any emotional problem in which drinking was part of the problem?; 21. Have you been arrested more than once for driving under the influence of alcohol?; 22. Have you ever been arrested, even for a few hours, because of other behavior while drinking? | 22 8-15 min | This quiz is scored by allocating 1 point to each ‘yes’ answer - except for questions 1 and 4, where 1 point is allocated for each ‘no’ answer - and totaling the responses. ≥5 is a positive screen for possible alcoholism
MAST-G | All items are yes/no questions; 1. After drinking have you ever noticed an increase in your heart rate or beating in your chest?; 2. When talking to others, do you ever underestimate how much you actually drank?; 3. Does alcohol make you sleepy so that you often fall asleep in your chair?; 4. After a few drinks, have you sometimes not eaten or been able to skip a meal because you didn’t feel hungry?; 5. Does having a few drinks help you decrease your shakiness or tremors?; 6. Does alcohol sometimes make it hard for you to remember parts of the day or night?; 7. Do you have rules for yourself that you won’t drink before a certain time of the day?; 8. Have you lost interest in hobbies or activities you used to enjoy?; 9. When you wake up in the morning, do you ever have trouble remembering part of the night before?; 10. Does having a drink help you sleep?; 11. Do you hide your alcohol bottles from family members?; 12. After a social gathering, have you ever felt embarrassed because you drank too much?; 13. Have you ever been concerned that drinking might be harmful to your health?; 14. Do you like to end an evening with a night cap?; 15. Did you find your drinking increased after someone close to you died?; 16. In general, would you prefer to have a few drinks at home rather than go out to social events?; 17. Are you drinking more now than in the past?; 18. Do you usually take a drink to relax or calm your nerves?; 19. Do you drink to take your mind off your problems?; 20. Have you ever increased your drinking after experiencing a loss in your life?; 21. Do you sometimes drive when you have had too much to drink?; 22. Has a doctor or nurse ever said they were worried or concerned about your drinking?; 23. Have you ever made rules to manage your drinking?; 24. When you feel lonely, does having a drink help? | 24 10 min | This quiz is scored by allocating 1 point to each ‘yes’ answer; ≥5 is a positive screen for possible alcoholism
NET | 1. N: normal drinker: do you feel you are a normal drinker?; 2. E: eye-opener question from CAGE; 3. T: tolerance: how many drinks does it take to make you feel high? (>2 indicates tolerance) | 3 1 min | Score 1 point each for not normal or eye openers and 2 points for tolerance; range 0–4
NIAAA Youth Guide Screening Questions | - Do you have any friends who drank beer, wine, or any drink containing alcohol in the past year? (Ages 9-14 years, this question first. Ages 14-18 users, this question second); - In the past year, on how many days have you had more than a few sips of beer, wine, or any drink containing alcohol?^‡^ | 2 1 min | Identify lower, moderate, or highest risk level using an age-specific chart
shARPS | Includes items in the following: domains:; - presence of medical and psychiatric conditions (8 items);; - symptoms of disease (7 items);; - medication use (11 items),; - physical function and health status (1 item);; - quantity and frequency of alcohol use (2 items);; - episodic heavy drinking (1 item);; - symptoms of alcohol abuse and dependence (1 items); and; - driving after drinking (1 item) | 32 2-5 min | Developed for older adults Complex scoring algorithm Classifies as harmful/hazardous, or nonhazardous
Single question: 12 months (NIAAA-recommended) | “How many times in the past year have you had X or more drinks in a day?” (X = 5 for men and 4 for women). | 1 1 min | ≥1 is a positive screen
Single question: 3 months (often called SASQ) | “When was the last time you had more than X drinks in 1 day?” where X was 4 for women and X was 5 for men Alternate wording: “On any single occasion during the past 3 months, have you had more than 5 drinks containing alcohol?” | 1 1 min | Positive if answer is within past 3 months. Positive if answer is yes.
SMAST | 1. Do you feel you are a normal drinker?; 2. Do your spouse, parents or other close relative worry or complain about your drinking?; 3. Do you ever feel guilty about your drinking?; 4. Do friends or relatives think you are a normal drinker?; 5. Are you able to stop drinking when you want to?; 6. Have you ever attended a meeting of Alcoholics Anonymous?; 7. Has your drinking ever caused problem between you, a spouse, parents or close relative?; 8. Have you ever got into trouble at work because of drinking?; 9. Have you ever neglected your obligations your family or your work for 2 or more days in a row because you were drinking?; 10. Have you ever gone to anyone for help about your drinking?; 11. Have you ever been in a hospital because of drinking?; 12. Have you ever been arrested for drunk driving or driving after drinking?; 13. Have you ever been arrested, however short a time, because of drinking? | 13 5 min | This quiz is scored by allocating 1 point to each ‘yes’ answer ≥2 is a positive screen for possible alcoholism
SMAST-G | 1. When talking to others, do you ever underestimate how much you actually drank?; 2. After a few drinks, have you sometimes not eaten or been able to skip a meal because you didn’t feel hungry?; 3. Does having a few drinks help you decrease your shakiness or tremors?; 4. Does alcohol sometimes make it hard for you to remember parts of the day or night?; 5. Do you usually take a drink to relax or calm your nerves?; 6. Do you drink to take your mind off your problems?; 7. Have you ever increased your drinking after experiencing a loss in your life?; 8. Has a doctor or nurse ever said they were worried or concerned about your drinking?; 9. Have you ever made rules to manage your drinking?; 10. When you feel lonely, does having a drink help? | 10 NR | This quiz is scored by allocating 1 point to each ‘yes’ answer ≥2 is a positive screen for possible alcoholism
T-ACE | - T: tolerance: how many drinks does it take to make you feel high? (>2 indicates tolerance); - A: have people annoyed you by criticizing your drinking?; - C: have you ever felt you should cut down on your drinking?; - E: eye-opener: have you ever had a drink first thing in the morning to steady your nerves or to get rid of a hangover? | 4 1 min | Score 2 points for tolerance; 1 point for others; range 0–5; threshold for positive score ≥2
TWEAK | - T: tolerance: how many drinks can you hold (‘hold’ version >5 indicates tolerance) or how many drinks can take before you begin to feel the effects (‘high’ version >2 indicates tolerance); - W: have close friends or relatives worried or complained about your drinking in the last year?; - E: eye-openers: do you sometimes take a drink in the morning when you first get up?; - A: amnesia: has a friend or family member ever told you about things you said or did while you were drinking that you could not remember?; - K: kut down: do you sometimes feel the need to cut down on your drinking? | 5 <2 min | Score 2 points each for first 2 items and 1 point each for last 3; range 0–7 positive score ≥2

* Table source: Jonas et al., 2012.^83^

† The original MAST included 25 questions and used a more complex scoring method; the version presented here represents the revised version used in practice today.

‡ This question is used in the Brief Screener for Tobacco, Alcohol, and other Drugs (BSTAD) to screen for alcohol use.