# Appendix B Epidemiology of the Health Effects of Alcohol Use

## Evidence Supporting Current Recommended Limits

The National Institute on Alcohol Abuse and Alcoholism (NIAAA) recommends that men ages 21 to 64 years consume no more than four drinks per day and no more than 14 drinks per week (56 grams/day or 196 grams/week). Corresponding values for nonpregnant women and men aged 65 years and old are no more than three drinks per day and no more than 14 drinks per week (56 grams/day or 196 grams/week). The evidence regarding the association between average daily volume (ADV) of alcohol intake and mortality and morbidity generally supports these limits. A 2006 meta-analysis including 34 prospective cohort studies of all-cause mortality found that mortality risk begins to exceed the level of nondrinkers at an ADV of approximately 38 grams of ethanol (2.7 standard drinks, according to the U.S. standard of 14g per drink).^33^ Sex-specific dose response curves in the same meta-analysis found that the risk of all-cause mortality began to increase at a lower ADV for women (~35 grams) than men (~45 grams). Similar risk levels have been reported in older meta-analyses, with risk of all-cause mortality becoming higher for drinkers compared with nondrinkers at ADV 30 to 50 grams for women and 40 to 70 grams for men.^7,^ ^301^ The evidence regarding the increased risk of cardiovascular disease has been mixed, with some studies indicating a protective effect at lower levels of consumption, however recent evidence cautions that this effect may be misrepresented.^8,^ ^33,^ ^302^ A meta-analysis of 28 studies found an increased risk of coronary heart disease compared with nondrinkers at a heavy volume of consumption (ADV 89 grams, or 6.4 drinks/day).^34^ In addition, researchers found an increased risk of hemorrhagic stroke (ADV 50 grams, 3.6 drinks/day), ischemic stroke (ADV 100 grams, 7.1 drinks/day), and type 2 diabetes (men: ADV 60 grams, 4.3 drinks/day; women: ADV 50 grams, 3.6 drinks/day) in drinkers compared with abstainers.^34,^ ^303^ The results for stroke are similar to those found in another meta-analysis of 35 observational studies, however the evidence around the risk of type 2 diabetes have been mixed.^304–306^

Evidence has shown that there is a dose-response relationship between alcohol intake and the risk of liver disease and cancer, with similar levels of increased harm reported for both conditions.^8^ The risk of developing liver cirrhosis was found to be increased at an ADV of 25 grams (or 1.8 drinks/day), with the increased risk for all types of liver disease reported at lower levels of consumption in women (7–13 drinks per week) than men (14–27 drinks per week).^34^ Evidence supports a likely causal relationship between excessive alcohol consumption and cancers of the oral cavity, pharyngeal, laryngeal, esophageal, liver, colon, rectal, and female breast.^8,^ ^304,^ ^307^ The meta-analysis by Corrao and colleagues found that the risk of developing pharyngeal, oral, colon, rectal, esophageal, laryngeal, liver, and breast cancers was significantly increased in drinkers compared with abstainers at ADVs of 25 grams and higher.^34^ These results were similar to those reported in other recent meta-analyses.^8,^ ^308–310^ However, the association between light to moderate alcohol consumption and cancer is less clear, and may vary by sex and cancer site. A 2015 systematic review and meta-analysis of two large U.S. cohort studies (n=135,965) found a small, but significant association between light to moderate drinking (<15 g/day for women and <30 g/day for men) and overall alcohol-related cancer risk when compared with abstainers.^311^ The risk of alcohol-related cancer among men was weaker than that among women, largely due to the strong association between light (5-14.9 g/day) consumption and female breast cancer (RR=1.13 [95% CI, 1.06 to 1.20]).^311^ Similarly, a 2013 systematic review and meta-analysis of 222 case-control and cohort studies found that light drinking (≤12.5 g/day) increased the risk of esophageal squamous cell carcinoma (RR=1.30 [95% CI, 1.09 to 1.56]), oral cavity and pharynx cancer (RR=1.17 [95% CI, 1.06 to 1.29]), and female breast cancer (RR=1.05 [95% CI, 1.02 to 1.08]).^312^ However, this review did not find evidence of increased risk for cancer of the colorectum, liver, or larynx.^312^

NIAAA recommends that pregnant women avoid alcohol altogether. Excessive alcohol use during pregnancy has been associated with adverse pregnancy outcomes, such as preterm birth, low birth weight, and Fetal Alcohol Spectrum Disorders.^313,^ ^314^ According to the U.S. Centers for Disease Control and Prevention (CDC),^315^ there is no known safe amount of alcohol use during pregnancy or while trying to get pregnant; however, there has been considerable debate regarding whether low to moderate drinking is associated with adverse birth outcomes. A 2011 systematic review of 36 case control and cohort studies investigated the dose-response relationship between alcohol consumption before and during pregnancy and risks of low birth weight, preterm birth, and small-size-for-gestational age (SGA), and found that, compared with abstainers, the risk of low birth weight and SGA had no effect up to 10 grams/day and preterm birth had no effect up to 18 grams/day of pure alcohol consumption.^316^ Other reviews examining the effects of low to moderate prenatal alcohol exposure have had similar findings, citing a lack of consistent effect of alcohol on adverse pregnancy outcomes.^317–319^ However, some evidence suggests that low to moderate alcohol use during pregnancy may have more subtle effects on cognitive and neurological development, and that the prevalence of adverse pregnancy outcomes may depend on other factors, including the mother’s socioeconomic status.^320,^ ^321^

Due to its ability to impair vision, psychomotor skills/abilities, reaction-time, and risk-taking judgment, alcohol has been associated with both intentional and unintentional injuries.^8^ Alcohol is commonly used prior to suicide.^322^ The risk of injury and violence is increased with ADV of 25 grams (1.8 drinks/day, RR=1.12, 95% CI 1.06-1.18).^34^ According to CDC, 7,266 suicides (23%) and 243,516 years of potential life lost (YPLL) were attributable to alcohol annually in 2001–2005.^322^ Alcohol also plays a key role in motor vehicle accidents, and even very low levels of consumption may impair driving. In general, the relationship between alcohol use and risk of motor vehicle accidents has been shown to be exponential.^8,^ ^323^ For example, dose-response curves suggest that consumption of 10 gram of pure alcohol is associated with a 24% increase in the odds of a motor vehicle accident (OR=1.24, 95% CI 1.18 to 1.31), while consumption of 120 grams is associated with an 52-fold increase (OR=52.0, 95% CI, 34.50 to 78.28).^324^ The legal limit of blood alcohol concentration (BAC) for operating a motor vehicle in all but one state in the United States is 0.08 g per 100 ml blood; however, there is evidence that BAC as low as 0.03 g/ml can impair faculties necessary for safe driving, such as vision, psychomotor skills/abilities, and reactiontime.^325^ A BAC as low as 0.02 g/ml is associated with a 74% increase in the odds of a fatal motor vehicle injury (OR=1.74, 95% CI, 1.43 to 2.14); at a BAC of 0.08 g/ml the odds are much higher (OR=13.0, 95% CI, 11.1 to 15.2).^326^ Further, positive BACs in drivers younger than 21 as associated with higher relative crash risks.^327^

## Evidence for the Benefits of Reducing Alcohol Use

While the relationship between excessive alcohol use and mortality is well established in the epidemiological literature,^328,^ ^329^ the effect of reducing alcohol consumption and whether “safe” levels of alcohol use exist are still matters of public health debate. Several reviews have investigated the association between reductions in volume of alcohol use and all-cause mortality. A 2013 systematic review of 16 studies among individuals with alcohol use disorders at baseline found that mortality risk decreased by more than half in individuals who reduced their drinking to abstention compared with those who continued heavy drinking (OR=0.35 [95% CI, 0.20 to 0.60]).^266^ Further, participants who reduced their drinking to below the study’s definition of heavy consumption (which varied across studies), but did not attain abstinence, also reduced their risk of mortality compared with those who continued heavy drinking (OR=0.61; 95% CI, 0.39 to 0.94).^266^ Another systematic review of 87 studies found that higher- (≥65 grams/day, or 4.6 U.S. drinks/day) and medium-volume (25–<45 g/day, 1.8 to 3.2 drinks/day) drinkers had a significantly higher risk of mortality compared with occasional drinkers (RR=1.52 [95% CI, 1.40 to 1.66] and RR=1.13 [95% CI, 1.05 to 1.22] respectively).^330^

Studies have shown that higher levels of alcohol consumption are associated with increased blood pressure and the incidence of hypertension.^8,^ ^331,^ ^332^ However, there is evidence that the detrimental effects of alcohol on hypertensive heart disease can be mitigated by reducing alcohol consumption, especially among heavy drinkers. A 2017 systematic review and meta-analysis of 36 randomized controlled trials found that heavy drinkers (those drinking ≥6 drinks/day, where one drink=12 g) who reduced their drinking by 50 percent had significant improvements in systolic (MD= −5.50 mm Hg [95% CI, −6.70 to −4.30]) and diastolic blood pressure (MD= −3.97 [95% CI, −4.70 to −3.25]).^333^ However, this association did not hold true for moderate drinkers (2–3 drinks/day).^333^ Similarly, a 2001 systematic review and meta-analysis of 15 randomized controlled trials found that individuals who consumed ≥3 drinks/day at baseline and had significantly reduced their drinking by any amount experienced a significant reduction in systolic (MD= −3.31 mm Hg [95% CI, −2.52 to −4.10]) and diastolic blood pressure (MD= −2.04 mm Hg [95% CI, −1.49 to −2.58]).^334^

## Evidence Related to a Protective Effect of Alcohol Use on Cardiovascular Disease and Cognitive Impairment

Some studies have characterized the relationship between alcohol consumption and various chronic conditions as a J-shaped curve, with slightly greater risk among abstainers compared with low to moderate drinkers, and progressive disease as drinking increases.^335,^ ^336^ This association has been most strongly supported by studies examining the association between low to moderate alcohol consumption and ischemic heart disease (IHD). A meta-analysis examining the impact of low to moderate alcohol consumption (<30 grams/day) on IHD risk found that moderate drinkers without heavy drinking episodes had a significantly lower risk for IHD than lifetime abstainers (RR=0.64 [95% CI, 0.53 to 0.71]), whereas moderate drinkers who engaged in heavy drinking episodes had a slight, but statistically nonsignificant, higher risk for IHD (RR=1.12 [95% CI, 0.91 to 1.37]).^337^

Similarly, some studies have reported a protective effect in the association between low levels of alcohol consumption and varying degrees of cognitive impairment. A 2008 systematic review of 23 studies found evidence to suggest that small amounts of alcohol may protect against dementia (RR=0.63 [95% CI, 0.53 to 0.75]), but not for vascular dementia or general cognitive decline for older adults, aged ≥65 years, when compared with nondrinkers.^338^ The analysis identified a wide range within its included studies in which low to moderate alcohol consumption was found to be beneficial for reducing risk of dementia, from ≥1 drink/day to 1—28 units/week.^338^ Similarly, a meta-analysis of 15 studies found significant beneficial effects for light to moderate drinkers (range 1-28 drinks/week, varying by study) and dementia (RR=0.74 [95% CI, 0.61 to 0.91]), but also for vascular dementia (RR=0.75 [95% CI, 0.57 to 0.98]) and Alzheimer disease (RR=0.72 [95% CI, 0.61 to 0.86]) among older drinkers when compared with nondrinkers.^339^ On the other hand, this review did not find a beneficial effect of low to moderate alcohol consumption on cognitive decline.^339^

However, this so-called “protective effect” remains controversial due to the potential misclassification of former heavy drinkers as abstainers in those studies, biasing the results in favor of light to moderate drinkers.^340^ For example, a meta-analysis examining the protective effect of moderate alcohol use on all-cause mortality found that estimates of mortality risk from alcohol were significantly altered by study design and characteristics, such as the misclassification of former drinkers as abstainers and lack of adjustment for confounding lifestyle variables.^330^ Moreover, a recent review summarized reasons for skepticism about the effects of low-dose alcohol consumption, including the lack of controlled studies investigating the association, the biological mechanisms for the health benefits being recently disconfirmed, evidence for adverse physiological effects of low-dose alcohol consumption, publication bias, and various confounding study population characteristics (e.g., benefits observed predominantly in Caucasian populations, moderate drinkers generally have healthier lifestyles, systematic exclusion of unhealthy drinkers).^340^