# Appendix A Detailed Methods

Abbreviations
4P’s Plus: = Past use, Pregnancy, use by Parents and Partners
5 A’s: = Ask, Advise, Assess, Assist, Arrange
AAP: = American Academy of Pediatrics
ACOG: = American College of Obstetricians and Gynecologists
ADHD: = Attention Deficit Hyperactivity Disorder
ADI: = Adolescent Drinking Index
ADV: = average daily volume
AHRQ: = Agency for Healthcare Research and Quality
AREAS: = Academic Role Expectations and Alcohol Scale
ARPS: = Alcohol-Related Problems Survey
ASAM: = American Society of Addiction Medicine
ASI: = Addictions Severity Index
ASSIST: = Alcohol, Smoking and Substance Involvement Screening Test
AUD: = Alcohol Use Disorder
AUDADIS: = Alcohol Use Disorder and Associated Disabilities Interview Schedule
AUDIT: = Alcohol Use Disorders Identification Test
AUDIT-C: = Alcohol Use Disorders Identification Test, Consumption
BRFSS: = Behavioral Risk Factor Surveillance System
BSTAD: = Brief Screener for Tobacco, Alcohol, and other Drugs
CAGE: = Cut-down, Annoyed, Guilty, Eye-opener
CARET: = Comorbidity Alcohol Risk Evaluation Tool
CI: = confidence interval
CIDI: = Composite International Diagnostic Interview
CRAFFT: = Car, Relax, Alone, Forget, Family, Friends, Trouble
DISC-IV: = Diagnostic Interview Schedule for Children, Version Four
DSM-5: = Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition
DSM-IV: = Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition
ED: = emergency department
FASDs: = fetal alcohol spectrum disorders
FDA: = Food and Drug Administration
FRAMES: = Feedback, Responsibility, Advice, Menu, Empathy, Self-efficacy
GRADE: = Grading of Recommendations Assessment, Development and Evaluation
HIV: = human immunodeficiency virus
ICD: = International Statistical Classification of Diseases and Related Health Problems
KQ: = Key Question
M/F: = men/women
MI: = Motivational Interviewing
MINI-Plus: = Mini International Neuropsychiatric Interview Plus
NESARC: = National Epidemiologic Survey on Alcohol and Related Conditions
NET: = Normal drinker, Eye opener, Tolerance
NIAAA: = National Institute on Alcohol Abuse and Alcoholism
NNT: = number needed to treat
NR: = not reported
NSDUH: = National Survey on Drug Use and Health
OR: = odds ratio
PMPM: = per member per month
RAPI: = Rutgers Alcohol Problem Index
RCT: = randomized controlled trial
REML: = restricted maximum likelihood
RR: = risk ratio
SASQ: = Single Item Alcohol Screening Questionnaire
SBIRT: = Screening, Brief Intervention, Referral, and Treatment
SES: = socioeconomic status
shARPS: = Short Alcohol-Related Problems Survey
SIP: = Short Inventory of Problems
STI: = sexually transmitted infection
T-ACE: = Tolerance-Annoyed, Cut-down, Eye-opener
TLFB: = Timeline Followback
TrEAT: = Trial for Early Alcohol Treatment
TWEAK: = Tolerance, Worried, Eye-openers, Amnesia, Kut-down
U.K.: = United Kingdom
U.S.: = United States
USAUDIT: = Alcohol Use Disorders Identification Test, United States
USAUDIT-C: = Alcohol Use Disorders Identification Test-Consumption, United States
USPSTF: = U.S. Preventive Services Trask Force
VA: = United States Department of Veterans Affairs
WHO: = World Health Organization
WIC: = Women, Infants, and Children
WMD: = weight mean difference

## Literature Search Strategies for Primary Literature

Key:

- / = subject heading
- $ = truncation
- *=truncation
- ab = word in abstract
- adj# = adjacent within x number of words
- hw = subject heading word
- id = key phrase identifier
- kw = keyword
- md = methodology
- pt = publication type
- ti = word in title

*Note: The scope of the review initially contained medicated-assisted therapy, which is reflected in the search strategy below.

Cochrane Central Register of Controlled Trials (CENTRAL)

Issue 9 of 12, September 2016

#1 | alcohol*:ti,ab,kw near/1 (use* or abuse* or misuse* or depend* or addict* or excess* or harmful or risk* or hazardous or problem* or unhealthy):ti,ab,kw
#2 | (harmful* or risk* or hazardous or problem* or binge* or heavy or excessive or unhealthy):ti,ab,kw next drink*:ti,ab,kw
#3 | “heavy episodic”:ti,ab,kw
#4 | #1 or #2 or #3
#5 | screen*:ti,ab,kw
#6 | assessment:ti,ab,kw next (tool* or instrument*):ti,ab,kw
#7 | (alcohol*):ti,ab,kw near/5 (scale* or inventor* or questionnaire* or survey* or index* or checklist* or interview*):ti,ab,kw
#8 | #5 or #6 or #7
#9 | “Alcohol Use Disorders Identification Test”:ti,ab,kw
#10 | AUDIT-C:ti,ab,kw
#11 | “Alcohol Smoking and Substance Involvement Screening Test”:ti,ab,kw
#12 | SASQ:ti,ab,kw
#13 | “Single Alcohol Screening”:ti,ab,kw next question*:ti,ab,kw
#14 | “National Institute on Alcohol Abuse and Alcoholism Single Item”:ti,ab,kw
#15 | “NIAAA Single Item”:ti,ab,kw
#16 | “Cut down Annoyed Guilty Eye-opener”:ti,ab,kw
#17 | “Brief Screener for Tobacco Alcohol and other Drugs”:ti,ab,kw
#18 | BSTAD:ti,ab,kw
#19 | “Comorbidity Alcohol Risk Evaluation Tool”:ti,ab,kw
#20 | “Tolerance Annoyed Cut down Eye opener”:ti,ab,kw
#21 | “Tolerance Worried Eye-opener Amnesia Kut down”:ti,ab,kw
#22 | SMAST-AID:ti,ab,kw
#23 | “4Ps Plus”:ti,ab,kw
#24 | “Substance Use Risk Profile-Pregnancy”:ti,ab,kw
#25 | {Rands, #9-`#24}
#26 | #4 and (#8 or #25) Publication Year from 2011 to 2016, in Trials
#27 | (sensitivit* or specificit*):ti,ab,kw
#28 | “predictive value”:ti,ab,kw
#29 | accuracy:ti,ab,kw
#30 | false:ti,ab,kw next (negativ* or positiv*):ti,ab,kw
#31 | (miss or error):ti,ab,kw next rate*:ti,ab,kw
#32 | (advice or advise*):ti,ab,kw
#33 | ROC:ti,ab,kw next curve*:ti,ab,kw
#34 | receiver:ti,ab,kw next operat*:ti,ab,kw
#35 | {or #27-#34}
#36 | (#4 and #8) or #25
#37 | #35 and #36 Publication Year from 1998 to 2016, in Trials
#38 | alcohol:ti,ab,kw near/1 reduc*:ti,ab,kw
#39 | alcohol:ti,ab,kw next (therap* or treatment*):ti,ab,kw
#40 | controlled:ti,ab,kw next drink*:ti,ab,kw
#41 | naltrexone:ti,ab,kw
#42 | revia:ti,ab,kw
#43 | depade:ti,ab,kw
#44 | vivitrol:ti,ab,kw
#45 | acamprosate:ti,ab,kw
#46 | campral:ti,ab,kw
#47 | disulfiram:ti,ab,kw
#48 | antabuse:ti,ab,kw
#49 | antabus:ti,ab,kw
#50 | counsel*:ti,ab,kw
#51 | behavio*:ti,ab,kw and chang*:ti,ab,kw
#52 | behavio*:ti,ab,kw and intervention*:ti,ab,kw
#53 | behavio*:ti,ab,kw and modification*:ti,ab,kw
#54 | (motivational next interview*):ti,ab,kw
#55 | (cognitive next behavio*):ti,ab,kw or cbt:ti,ab,kw
#56 | behavio*:ti,ab,kw and therapy:ti,ab,kw
#57 | (brief next intervention*):ti,ab,kw
#58 | “self help”:ti,ab,kw
#59 | computer:ti,ab,kw next (based or mediated or assisted):ti,ab,kw
#60 | email*:ti,ab,kw or internet:ti,ab,kw or (text next messag*):ti,ab,kw or web:ti,ab,kw or website:ti,ab,kw
#61 | “patient education”:ti,ab,kw or “health education”:ti,ab,kw or “health promotion”:ti,ab,kw
#62 | “12 step”:ti,ab,kw or “twelve step”:ti,ab,kw or “alcoholics anonymous” or AA:ti,ab,kw
#63 | intervention*:ti or psychosocial:ti
#64 | {or #38-#63}
#65 | #4 and #64 Publication Year from 2011 to 2016, in Trials
#66 | #26 or #37 or #65

Ovid Medline, Ovid MEDLINE In-Process & Other Non-Indexed Citations, Ovid MEDLINE Daily Update

1 | Alcohol-Related Disorders/
2 | Alcoholic intoxication/
3 | Alcoholism/
4 | Binge Drinking/
5 | (alcohol$ adj1 (use$ or abuse$ or misuse$ or depend$ or addict$ or excess$ or harmful or risk$ or hazardous or problem$ or unhealthy)).ti,ab.
6 | ((harmful$ or risk$ or hazardous or problem$ or binge$ or heavy or excessive or unhealthy) adj drink$).ti,ab.
7 | heavy episodic.ti,ab.
8 | or/1-7
9 | Mass screening/
10 | screen$.ti,ab.
11 | (assessment adj (tool$ or instrument$)).ti,ab.
12 | (alcohol$ adj5 (scale$ or inventor$ or questionnaire$ or survey$ or index$ or checklist$ or interview$)).ti,ab.
13 | Substance Abuse Detection/
14 | or/9-13
15 | “Alcohol Use Disorders Identification Test”.ti,ab.
16 | AUDIT-C.ti,ab.
17 | “Alcohol Smoking and Substance Involvement Screening Test”.ti,ab.
18 | SASQ.ti,ab.
19 | Single Alcohol Screening Question$.ti,ab.
20 | “National Institute on Alcohol Abuse and Alcoholism Single Item”.ti,ab.
21 | NIAAA Single Item.ti,ab.
22 | Cut down Annoyed Guilty Eye-opener.ti,ab.
23 | “Brief Screener for Tobacco Alcohol and other Drugs”.ti,ab.
24 | BSTAD.ti,ab.
25 | Comorbidity Alcohol Risk Evaluation Tool.ti,ab.
26 | Tolerance Annoyed Cut down Eye opener.ti,ab.
27 | Tolerance Worried Eye-opener Amnesia Kut down.ti,ab.
28 | or/15-27
29 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
30 | (clinical trial or controlled clinical trial or randomized controlled trial).pt.
31 | Random$.ti,ab.
32 | control groups/ or double-blind method/ or single-blind method/
33 | clinical trial$.ti,ab.
34 | controlled trial$.ti,ab.
35 | or/29-34
36 | 8 and (14 or 28) and 35
37 | “Sensitivity and Specificity”/
38 | “Predictive Value of Tests”/
39 | ROC Curve/
40 | False Negative Reactions/
41 | False Positive Reactions/
42 | Diagnostic Errors/
43 | “Reproducibility of Results”/
44 | Reference Values/
45 | Reference Standards/
46 | Observer Variation/
47 | Receiver operat$.ti,ab.
48 | ROC curve$.ti,ab.
49 | sensitivit$.ti,ab.
50 | specificit$.ti,ab.
51 | predictive value.ti,ab.
52 | accuracy.ti,ab.
53 | false positive$.ti,ab.
54 | false negative$.ti,ab.
55 | miss rate$.ti,ab.
56 | error rate$.ti,ab.
57 | or/37-56
58 | (8 and 14) or 28
59 | 57 and 58
60 | limit 59 to (english language and yr="1998 -Current”)
61 | Animals/ not (Humans/ and Animals/)
62 | 60 not 61
63 | remove duplicates from 62
64 | Alcohol deterrents/
65 | (alcohol adj1 reduc$).ti,ab.
66 | (alcohol adj (therap$ or treatment$)).ti,ab.
67 | controlled drink$.ti,ab.
68 | Naltrexone/
69 | naltrexone.ti,ab.
70 | revia.ti,ab.
71 | depade.ti,ab.
72 | vivitrol.ti,ab.
73 | acamprosate.ti,ab.
74 | campral.ti,ab.
75 | Disulfiram/
76 | disulfiram.ti,ab.
77 | antabuse.ti,ab.
78 | antabus.ti,ab.
79 | Behavior Therapy/
80 | Cognitive Therapy/
81 | Counseling/
82 | Directive Counseling/
83 | Patient Education as Topic/
84 | Risk Reduction Behavior/
85 | Feedback, psychological/
86 | Health education/
87 | Health promotion/
88 | Motivation/
89 | Internet/
90 | Motivational interviewing/
91 | Persuasive communication/
92 | Self-help groups/
93 | Text messaging/
94 | Therapy, computer-assisted/
95 | (advice or advise$).ti,ab.
96 | counsel$.ti,ab.
97 | behavio?r$ chang$.ti,ab.
98 | behavio?r$ intervention$.ti,ab.
99 | behavio?r$ modification$.ti,ab.
100 | motivational interview$.ti,ab.
101 | (cognitive behavio$ or behavio$ therapy or cbt).ti,ab.
102 | brief intervention$.ti,ab.
103 | self help.ti,ab.
104 | text messag$.ti,ab.
105 | (web or website).ti,ab.
106 | (computer adj (based or mediated or assisted)).ti,ab.
107 | 12 step.ti,ab.
108 | twelve step.ti,ab.
109 | Alcoholics Anonymous/
110 | alcoholics anonymous.ti,ab.
111 | (intervention$ or psychosocial).ti.
112 | or/64-110
113 | 8 and 112
114 | Alcohol-Related Disorders/dt, pc, rh, th [Drug Therapy, Prevention & Control, Rehabilitation, Therapy]
115 | Alcoholic intoxication/dt, pc, rh, th
116 | Alcoholism/dt, pc, rh, th
117 | Binge Drinking/dt, pc, rh, th
118 | 113 or 114 or 115 or 116 or 117
119 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
120 | (clinical trial or controlled clinical trial or randomized controlled trial).pt.
121 | Random$.ti,ab.
122 | control groups/ or double-blind method/ or single-blind method/
123 | clinical trial$.ti,ab.
124 | controlled trial$.ti,ab.
125 | 119 or 120 or 121 or 122 or 123 or 124
126 | 118 and 125
127 | 36 or 126
128 | limit 127 to (english language and yr="2011 -Current”)
129 | Animals/ not (Humans/ and Animals/)
130 | 128 not 129
131 | remove duplicates from 130
132 | 63 or 131

PsycInfo

1 | Alcohols/
2 | Alcohol Abuse/
3 | Alcohol Intoxication/
4 | Acute Alcoholic Intoxication/
5 | Chronic Alcoholic Intoxication/
6 | Binge Drinking/
7 | Alcoholism/
8 | (alcohol$ adj1 (use$ or abuse$ or misuse$ or depend$ or addict$ or excess$ or harmful or risk$ or hazardous or problem$ or unhealthy)).ti,ab,id.
9 | ((harmful$ or risk$ or hazardous or problem$ or binge$ or heavy or excessive or unhealthy) adj drink$).ti,ab,id.
10 | heavy episodic.ti,ab,id.
11 | or/1-10
12 | Screening/
13 | Health Screening/
14 | Screening Tests/
15 | Intake Interview/
16 | Symptom Checklists/
17 | Interviews/
18 | Questionnaires/
19 | Rating Scales/
20 | Self Report/
21 | General Health Questionnaire/
22 | Computer Assisted Diagnosis/
23 | screen$.ti,ab,id.
24 | (assessment adj (tool$ or instrument$)).ti,ab,id.
25 | (alcohol$ adj5 (scale$ or inventor$ or questionnaire$ or survey$ or index$ or checklist$ or interview$)).ti,ab,id.
26 | self report$.ti,ab,id.
27 | identif$.ti.
28 | or/12-27
29 | “Alcohol Smoking and Substance Involvement Screening Test”.ti,ab,tm.
30 | AUDIT-C.ti,ab,tm.
31 | “Alcohol Smoking and Substance Involvement Screening Test”.ti,ab,tm.
32 | SASQ.ti,ab,tm.
33 | Single Alcohol Screening Question$.ti,ab,tm.
34 | “National Institute on Alcohol Abuse and Alcoholism Single Item”.ti,ab,tm.
35 | NIAAA Single Item.ti,ab,tm.
36 | Cut down Annoyed Guilty Eye-opener.ti,ab,tm.
37 | “Brief Screener for Tobacco Alcohol and other Drugs”.ti,ab,tm.
38 | BSTAD.ti,ab,tm.
39 | Comorbidity Alcohol Risk Evaluation Tool.ti,ab,tm.
40 | Tolerance Annoyed Cut down Eye opener.ti,ab,tm.
41 | Tolerance Worried Eye-opener Amnesia Kut down.ti,ab,tm.
42 | or/29-41
43 | random$.ti,ab,id,hw.
44 | placebo$.ti,ab,hw,id.
45 | controlled trial$.ti,ab,id,hw.
46 | clinical trial$.ti,ab,id,hw.
47 | clinical trial.md.
48 | Experiment Controls/
49 | or/43-48
50 | 11 and (28 or 42) and 49
51 | limit 50 to (english language and yr="2011 -Current”)
52 | Test Validity/
53 | Test Reliability/
54 | Interrater Reliability/
55 | validity.ti,ab,id.
56 | reliability.ti,ab,id.
57 | Receiver operat$.ti,ab,id.
58 | ROC curve$.ti,ab,id.
59 | sensitivit$.ti,ab,id.
60 | specificit$.ti,ab,id.
61 | predictive value.ti,ab,id.
62 | accuracy.ti,ab,id.
63 | false positive$.ti,ab,id.
64 | false negative$.ti,ab,id.
65 | miss rate$.ti,ab,id.
66 | error rate$.ti,ab,id.
67 | or/52-66
68 | (11 and 28) or 42
69 | 67 and 68
70 | limit 69 to (english language and yr="1998 -Current”)
71 | Acamprosate/
72 | acamprosate.ti,ab,id.
73 | campral.ti,ab,id.
74 | Naltrexone/
75 | revia.ti,ab,id.
76 | depade.ti,ab,id.
77 | vivitrol.ti,ab,id.
78 | Disulfiram/
79 | disulfiram.ti,ab,id.
80 | antabuse.ti,ab,id.
81 | antabus.ti,ab,id.
82 | Alcohol Rehabilitation/
83 | Rehabilitation Counseling/
84 | (alcohol adj1 reduc$).ti,ab,id.
85 | (alcohol adj (therap$ or treatment$)).ti,ab,id.
86 | controlled drink$.ti,ab,id.
87 | Health Promotion/
88 | Motivation/
89 | Behavior Modification/
90 | Behavior Change/
91 | behavio?r$ chang$.ti,ab,id.
92 | behavio?r$ intervention$.ti,ab,id.
93 | behavio?r$ modification$.ti,ab,id.
94 | behavior therapy/
95 | cognitive behavior therapy/
96 | cognitive therapy/
97 | Cognitive Techniques/
98 | (cognitive behavio$ or behavio$ therapy or cbt).ti,ab,id.
99 | brief intervention$.ti,ab,id.
100 | Persuasive Communication/
101 | Motivational Interviewing/
102 | motivational interview$.ti,ab,id.
103 | Health Knowledge/
104 | Health Behavior/
105 | Health Education/
106 | Client Education/
107 | Feedback/
108 | Online Therapy/
109 | Computer Assisted Therapy/
110 | Computer Mediated Communication/
111 | Computer Assisted Testing/
112 | Internet/
113 | (computer adj (based or mediated or assisted)).ti,ab,id.
114 | text messag$.ti,ab,id.
115 | email$.ti,ab,id.
116 | internet.ti,ab,id.
117 | (web or website).ti,ab,id.
118 | Self Help Techniques/
119 | self help.ti,ab,id.
120 | counseling/
121 | Group Counseling/
122 | counseling.ti,ab,id.
123 | counselling.ti,ab,id.
124 | Alcoholics Anonymous/
125 | Twelve Step Programs/
126 | alcoholics anonymous.ti,ab,id.
127 | 12 step.ti,ab,id.
128 | twelve step.ti,ab,id.
129 | advice.ti,ab,id.
130 | advise$.ti,ab,id.
131 | (intervention$ or psychosocial).ti.
132 | or/71-131
133 | 11 and 49 and 132
134 | limit 133 to (english language and yr="2011 -Current”)
135 | 51 or 70 or 134

PubMed, publisher-supplied

#29 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #28 AND publisher[sb] AND (“2011/01/01"[Date - Publication]: “3000”[Date - Publication]) AND English[Language]
#28 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#9 OR #26) AND #27
#27 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search random*[tiab] OR clinical trial*[tiab] OR controlled trial*[tiab]
#26 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #4 AND #25
#25 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24
#24 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search intervention*[ti] OR psychosocial[ti]
#23 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “12 step”[tiab] OR “twelve step”[tiab] OR “alcoholics anonymous”[tiab]
#22 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “patient education”[tiab] OR “health education”[tiab] OR “health promotion”[tiab]
#21 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search email*[tiab] OR internet[tiab] OR text messag*[tiab] OR web[tiab] OR website[tiab] OR computer based[tiab] OR computer mediated[tiab] OR computer assisted[tiab]
#20 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search self help[tiab]
#19 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search brief intervention*[tiab]
#18 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search motivational interview*[tiab]
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search behavio* therap*[tiab]
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search cognitive behavio*[tiab] OR cbt[tiab]
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (behavio* chang*[tiab]) OR (behavio* intervention*[tiab]) OR (behavio* modification*[tiab])
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search counsel*[tiab]
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search naltrexone[tiab] OR revia[tiab] OR depade[tiab] OR vivitrol[tiab] OR acamprosate[tiab] OR campral[tiab] OR disulfiram[tiab] OR antabuse[tiab] OR antabus[tiab]
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search controlled drink*[tiab]
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search alcohol therap*[tiab] OR alcohol treatment*[tiab]
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search alcohol reduc*[tiab] OR reduc* alcohol[tiab]
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #4 AND #8
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 OR #6 OR #7
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search alcohol[tiab] AND (scale*[tiab] OR inventor*[tiab] OR questionnaire*[tiab] OR survey*[tiab] OR index*[tiab] OR checklist[tiab] OR interview[tiab])
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (assessment tool*[tiab] OR assessment instrument*[tiab])
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search screen*[tiab]
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 OR #2 OR #3
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “heavy episodic”[tiab]
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search harmful drink*[tiab] OR risky drink*[tiab] OR hazardous drink*[tiab] OR problem* drink*[tiab] OR binge drink*[tiab] OR heavy drink*[tiab] OR excessive drink*[tiab] OR unhealthy drink*[tiab]
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search alcohol use*[tiab] OR alcohol abuse*[tiab] OR alcohol misuse*[tiab] OR alcohol depend*[tiab] OR alcohol addict*[tiab] OR alcohol problem[tiab] OR harmful alcohol [tiab] OR risky alcohol [tiab] OR hazardous alcohol [tiab] OR unhealthy alcohol [tiab] OR excess* alcohol [tiab] OR alcoholism[title]

Appendix A Table 1 Comparison of DSM-IV and DSM-5 Alcohol-Related Disorders

DSM-IV | Symptoms (past year) | DSM-5
Any 1= Alcohol Abuse | Found that drinking (or being sick from drinking) often interfered with taking care of home or family responsibilities, caused problems at work, or caused problems at school. | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms
Any 1= Alcohol Abuse | More than once gotten into situations while or after drinking that increased the chances of getting hurt (e.g., driving, swimming, unsafe sexual behavior). | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms
Any 1= Alcohol Abuse | More than once gotten arrested, been held at a police station, or had other legal problems because of drinking (Not in DSM-5) | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms
Any 1= Alcohol Abuse | Continued to drink even though it was causing trouble with family and friends. | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms
Any 3 = Alcohol Dependence | Had to drink much more than previously in order to get the desired effect, or finding that the usual number of drinks had much less effect than previously. | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms
Any 3 = Alcohol Dependence | Experienced the symptoms of withdrawal after the effects of alcohol were wearing off, such as trouble sleeping, shakiness, restlessness, nausea, sweating, racing heart, or seizure. | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms
Any 3 = Alcohol Dependence | Had times when the patient drank more, or longer, than intended. | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms
Any 3 = Alcohol Dependence | More than once wanted to cut down or stop, tried it, but could not. | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms
Any 3 = Alcohol Dependence | Spent a lot of time drinking or being sick/getting over the aftereffects of drinking. | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms
Any 3 = Alcohol Dependence | Given up or cut back on activities that were important or interesting in order to drink. | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms
Any 3 = Alcohol Dependence | Continued to drink even though it was causing depression or anxiety, other health problems, or causing memory blackouts. | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms
| Wanted to drink so badly that the patient could not think of anything else. (Not in DSM-IV) | 2+ symptoms = Alcohol Use Disorder Mild: 2-3 symptoms Moderate: 4-5 symptoms Severe: 6+ symptoms

Abbreviations: DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, 4th Edition; DSM-5 = Diagnostic and Statistical Manual of Mental Disorders, 5th Edition.

Appendix A Table 2 Inclusion and Exclusion Criteria

Category | Included | Excluded
Aim | Screening for unhealthy alcohol use and interventions for nondependent unhealthy alcohol use, with or without addressing other substances or behaviors | Studies in which the only aim is targeting another behavior (e.g., drug or tobacco use) (i.e., change in alcohol use is not a stated aim, even if it is a reported outcome)
Condition | Unhealthy alcohol use^*^, including:; - Risky or hazardous use: consumption of alcohol above recommended daily, weekly, or per-occasion amounts; consumption levels that increase the risk for health consequences; - Harmful use: a pattern of drinking that is already causing damage to health; damage may be either physical (e.g., liver damage from chronic drinking) or mental (e.g., depressive episodes secondary to drinking); - A diagnosis of an alcohol use disorder (e.g., according to Diagnostic and Statistical Manual of Mental Disorders [DSM] or International Classification of Diseases [ICD] diagnostic systems
Population | All KQs: Adolescents and adults (age ≥12 years) KQs 1–3: Studies whose participants are not selected on the basis of alcohol use or a related behavior or condition KQs 4, 5: Studies in which at least 50% of the enrolled sample is recruited via population-based screening A priori subpopulations at greater risk for unhealthy alcohol use or its consequences will be examined based on the following: age, sex, race/ethnicity, socioeconomic status, pregnancy status, concurrent unhealthy drug use, severity of disorder, and presence of comorbid mental health conditions | Studies limited to:; - Treatment-seeking individuals (including those responding to recruitment advertising); - Persons with concomitant psychotic disorders (e.g., schizophrenia); - Persons presenting in an emergency setting for alcohol-related issues (e.g., motor vehicle injury); - Other groups not generalizable to primary care (e.g., psychiatric inpatients, persons who are court-mandated to treatment, incarcerated persons); - KQs 4, 5: Persons with dependent alcohol abuse (or studies in which >50% of the enrolled sample is persons with dependent alcohol use)
Screening | KQs 1, 3: Screening for alcohol use using a brief standardized instrument or set of questions that is conducted in person or via telephone, mail, or electronically KQ 2: Accuracy of screening instruments will be limited to the following instruments, which are most widely used and feasible for application in primary care:; - National Institute on Alcohol Abuse and Alcoholism (NIAAA) single- (for adults) or two-item (for adolescents) screening test, or comparable, including the Brief Screener for Tobacco, Alcohol, and other Drugs (BSTAD) (for adolescents); - Alcohol Use Disorders Identification Test (AUDIT), its abbreviated version (AUDIT-C), and variants of these; - Alcohol, Smoking, and Substance Involvement Screening Test (ASSIST) (for accuracy of detecting alcohol use only); - Comorbidity Alcohol Risk Evaluation Tool (CARET) (for the elderly); - TWEAK and T-ACE (for pregnant women) | - Studies without any screening instruments or question(s); - Laboratory tests
Interventions | - Counseling designed to reduce unhealthy alcohol use, with or without referral; - Counseling interventions can vary in their approach (e.g., 12-step program, cognitive behavioral therapy, motivational enhancement therapy), specific strategies (e.g., action plans, diaries), delivery method (e.g., face-to-face, electronic, individual, group-based), length of contact (e.g., brief, extended), and the number of contacts (e.g., single, multiple) | - Financial incentive; - Vocational rehabilitation; - Community-based media or policy interventions; - Interventions to prevent initiation of use among nonusers; - Pharmacotherapy
Comparators | KQs 1, 3: No screening or usual care KQ 2: Comparison with reference standard (i.e., structured or semistructured clinical interview) KQs 4, 5:; - No intervention; - Usual care; - Waitlist; - Attention control (e.g., intervention is similar in format and intensity but on a different content area); - Minimal intervention (e.g., no more than one single brief contact per year, brief written materials such as pamphlets) | Active intervention (e.g., comparators with a reasonable expectation of affecting change in alcohol consumption)
Setting | KQs 1–3: Population-based screening that takes place in a setting that is applicable to primary care, including: primary care clinics; prenatal clinics; obstetrics/gynecology clinics; specialty medical treatment settings (e.g., diabetes management, dialysis clinics); research clinics/office, home, or other community settings, including electronic or computer-based screening KQs 4, 5: Interventions in a screen-detected population that take place in a traditional primary care setting or one that is applicable to or referable from primary care, including: primary care clinics; prenatal clinics; obstetrics/gynecology clinics; school health clinics; behavioral/mental health clinics; substance abuse treatment centers; research clinics/office, home, or other community settings, including electronic or computer-based interventions. Screening to identify eligible participants must take place in broad-based, general settings comparable to primary care with a defined population (e.g., primary care clinic, Special Supplemental Nutrition Program for Women, Infants, and Children [WIC], college freshman orientation) | Screening that takes place in:; - Behavioral/mental health clinic; - Substance abuse treatment center; - Emergency department/trauma center; - Worksites, including occupational screening; - Inpatient/residential facility; - Other institutions (e.g., correctional facility)
Outcomes | KQs 1a, 4a:; - Alcohol use (required), self-report and/or biologic measures, including:; ○ Frequency and/or quantity of alcohol use; ○ Abstinence (use/no use); ○ Severity of alcohol use disorder (reported as an index measured by a standardized questionnaire, such as the Short Inventory of Problems, Addiction Severity Index, or the Severity of Dependence Scale); ○ Meeting criteria for alcohol use disorder; - Other risky behaviors (e.g., other drug use, risky sexual behaviors); KQs 1b, 4b:; - All-cause mortality; - Alcohol-related mortality (intentional and unintentional); - Alcohol-related morbidity (e.g., mental health symptoms/disorders; alcohol-related liver problems, including fatty liver disease, alcoholic hepatitis, and alcoholic cirrhosis; cancer; cardiovascular disease, such as cardiomyopathy; neuropathy; cognitive impairment; gastritis; gastric ulcers; pancreatitis; anemia; injuries, assaults, and accidents; visits to emergency department and inpatient stays); - Obstetrical/perinatal/neonatal outcomes (e.g., perinatal mortality, preterm labor/delivery, low birth weight, placental abruption, intrauterine growth restriction, preeclampsia, antepartum or postpartum hemorrhage, gestational hypertension, decreased neonate length/head circumference, neonate neurobehavioral effects, congenital anomalies, neonatal abstinence syndrome, neonatal intensive care unit admission, decreased length of neonate hospitalization, fetal alcohol spectrum disorders); - Quality of life; - Alcohol-related problems, such as legal problems, social and family relations, employment, and school/educational outcomes; KQ 2: Sensitivity and specificity or data to calculate one or both KQs 3, 5:; - Serious harms at any time point after the screening or intervention began (e.g., death, seizure, cardiovascular event, or other medical issue requiring urgent medical treatment; serious obstetrical/perinatal/neonatal complication attributable to included medications); - Demoralization due to failed quit attempt; - Stigma, labeling, and/or discrimination; - Privacy issues (e.g., insurability status); - Job loss; - Interference with the doctor-patient relationship | - Attitudes, knowledge, and beliefs related to alcohol use; - Intention to change behavior; - Intervention participation/compliance; - Alcohol use initiation
Outcome assessment timing | At least 6 months after baseline measurement (except for studies in pregnant women, for which shorter followup times will be included)
Study design | KQs 1, 3: Studies that compare individuals who receive screening with those receiving no screening or usual care, including randomized, controlled trials and nonrandomized controlled trials KQ 2: Studies of screening accuracy reporting sensitivity and specificity compared with a structured or semistructured clinical interview KQs 4, 5: Randomized, controlled trials and nonrandomized controlled trials | Prospective and retrospective cohort studies, case control studies, time series studies, before-after studies with no comparison group, cross-sectional studies, case studies, case series, and editorials/commentaries
Country | Studies conducted in countries categorized as “Very High” on the 2014 Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries that are not categorized as “Very High” on the 2014 Human Development Index
Publication date | Studies whose primary results were published from 1985 to present | Studies whose primary results were published prior to 1985
Publication language | English | Languages other than English
Quality | Fair or good quality | Poor quality (according to design-specific USPSTF criteria)

* According to the American Society of Addiction Medicine

Abbreviations: KQ = Key Question; USPSTF = U.S. Preventive Services Task Force.

Appendix A Table 3 Quality Assessment Criteria^*^

Study Design | Adapted Quality Criteria
Randomized and non-randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^85^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported
Test accuracy studies, adapted from QUADAS-2^299,^ ^300^ | Patient Selection; - Was a consecutive or random sample of patients enrolled?; - Did the study avoid inappropriate exclusions?; Index Test; - Were the index test results interpreted without knowledge of the reference standard results?; - If a threshold was used, was it prespecified or was a range of values presented?; Reference Standard; - Is the reference standard likely to correctly classify the target condition?; - Were the reference standard results interpreted without knowledge of the index test?; - Were staff trained in the use of the reference standard?; - Was fidelity of the reference standard monitored or reported?; Flow and Timing; - Was there an appropriate interval between the index test and reference standard?; - Did all patients receive a reference standard?; - Did all patients receive the same reference standard?; - Were all patients included in the analysis?

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.

Appendix A Figure 1 Analytic Framework

Figure 1 is the analytic framework that depicts the five Key Questions to be addressed in the systematic review. The figure illustrates how primary care screening for unhealthy alcohol use in adolescents and adults, including pregnant women, may reduce morbidity or mortality to improve other health, social, or legal outcomes (KQ1a), and how primary care screening for unhealthy alcohol use in adolescents and adults, including pregnant women, may reduce morbidity or mortality to improve other health, social, or legal outcomes (KQ1b). Additionally, the figure illustrates what the accuracy of commonly used instruments to screen for unhealthy alcohol use may be (KQ2), and what adverse events may be associated with screening for unhealthy alcohol use in adolescents and adults, including pregnant women (KQ3). Further, this figure illustrates how counseling interventions to reduce unhealthy alcohol use, with or without referral, may reduce alcohol use or improve other risky behaviors in screen-detected persons (KQ4a), and how counseling interventions to reduce unhealthy alcohol use, with or without referral, may reduce morbidity or mortality to improve other health, social, or legal outcomes in screen-detected persons (KQ4b). Finally, this figure illustrates what adverse events may be associated with interventions to reduce unhealthy alcohol use in screen-detected persons.

Appendix A Figure 2 Literature Flow Diagram

This figure is a flow chart that summarizes the search and selection of articles in the review. There were 31,820 citations identified through literature databases. An additional 45 citations were identified from outside sources such as reference lists and suggestions from peer reviewers, and 309 citations were from the 2013 USPSTF Alcohol Misuse review. After duplicates were removed, 17,149 unique citations were screened at the title/abstract stage. The full-text of 570 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=0), Key Question 2 (k=45), Key Question 3 (k=0), Key Question 4 (k=68), and Key Question 5 (k=11).