# References

1 Nelson HD, Selph S, Bougatsos C, . Behavioral Interventions and Counseling to Prevent Child Abuse and Neglect: Systematic Review to Update the U.S. Preventive Services Task Force Recommendation [Internet]. U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Report No.: 13-05176-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; Jan 2013. https://www.ncbi.nlm.nih.gov/pubmed/23390658 PMID: 2339065823390658.
2 Moyer VA. Primary care interventions to prevent child maltreatment: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013 Aug 20;159(4):289–95. doi: 10.7326/0003-4819-159-4-201308200-00667. PMID: 23752681.23752681
3 World Health Organization and International Society for Prevention of Child Abuse and Neglect. Preventing child maltreatment: a guide to taking action and generating evidence. Geneva, Switzerland: WHO Press; 2006. http://apps.who.int/iris/bitstream/10665/43499/1/9241594365_eng.pdf. Accessed on December 21, 2015.
4 Leeb RT, Paulozzi LJ, Melanson C, . Child Maltreatment Surveillance: Uniform Definitions for Public Health and Recommended Data Elements. Version 1.0. Atlanta, GA: Centers for Disease Control and Prevention; 2008. http://www.cdc.gov/violenceprevention/pdf/cm_surveillance-a.pdf. Accessed on 28 December, 2015.
5 U.S. Department of Health and Human Services, Administration for Children and Families, Administration on Children, Youth and Families, . The Child Abuse Prevention and Treatment Act as Amended by P.L. 111-320, The CAPTA Reauthorization Act of 2010 (42 U.S.C. 5106a). Washington, DC: U.S. Department of Health and Human Services, Administration for Children and Families; 2011. http://www.acf.hhs.gov/programs/cb/resource/capta2010. Accessed on August 7 2017.
6 Institute of Medicine, Council. NR. New directions in child abuse and neglect research. Washington, DC: The National Academies Press; 2014. http://www.nap.edu/catalog/18331/new-directions-in-child-abuse-and-neglect-research. Accessed on December 21, 2015.
7 U.S. Department of Health & Human Services, Administration for Children and Families, Administration on Children, Youth and Families, Children’s Bureau. Child Maltreatment 2016. Washington, DC: U.S. Department of Health & Human Services, Administration for Children and Families, Administration on Children, Youth and Families, Children’s Bureau; 2017. https://www.acf.hhs.gov/sites/default/files/cb/cm2016.pdf. Accessed on March 28 2018.
8 U.S. Department of Health & Human Services, Administration for Children and Families, Administration on Children, Youth and Families, Children’s Bureau. Child Maltreatment 2014. Washington, DC; 2016. https://www.acf.hhs.gov/cb/resource/child-maltreatment-2014. Accessed on August 3 2017.
9 U.S. Department of Health & Human Services, Administration for Children and Families, Administration on Children, Youth and Families, Children’s Bureau. Child Maltreatment 2015. Washington, DC: U.S. Department of Health & Human Services, Administration for Children and Families, Administration on Children, Youth and Families, Children’s Bureau; 2017. http://www.acf.hhs.gov/programs/cb/research-data-technology/statistics-research/child-maltreatment. Accessed on November 8 2017.
10 Jud A, Fegert JM, Finkelhor D. On the incidence and prevalence of child maltreatment: a research agenda. Child Adolesc Psychiatry Ment Health. 2016;10:17. doi: 10.1186/s13034-016-0105-8. PMID: 27303442.27303442
11 Sedlak AJ, Mettenburg J, Basena M, . Fourth National Incidence Study of Child Abuse and Neglect (NIS–4). Report to Congress. Executive Summary. Washington, DC: U.S. Department of Health and Human Services, Administration for Children and Families; 2010. http://www.acf.hhs.gov/sites/default/files/opre/nis4_report_exec_summ_pdf_jan2010.pdf. Accessed on February 10, 2016.
12 Drake B, Jolley JM, Lanier P, . Racial bias in child protection? A comparison of competing explanations using national data. Pediatrics. 2011 Mar;127(3):471–8. doi: 10.1542/peds.2010-1710. PMID: 21300678.21300678
13 Lanier P, Maguire-Jack K, Walsh T, . Race and ethnic differences in early childhood maltreatment in the United States. J Dev Behav Pediatr. 2014 Sep;35(7):419–26. doi: 10.1097/DBP.0000000000000083. PMID: 25180892.25180892
14 Finkelhor D, Turner HA, Shattuck A, . Prevalence of childhood exposure to violence, crime, and abuse: results from the National Survey of Children’s Exposure to Violence. JAMA Pediatr. 2015 Aug;169(8):746–54. doi: 10.1001/jamapediatrics.2015.0676. PMID: 26121291.26121291
15 MacMillan HL, Jamieson E, Walsh CA. Reported contact with child protection services among those reporting child physical and sexual abuse: results from a community survey. Child Abuse Negl. 2003 Dec;27(12):1397–408. PMID: 14644057.14644057
16 Everson MD, Smith JB, Hussey JM, . Concordance between adolescent reports of childhood abuse and Child Protective Service determinations in an at-risk sample of young adolescents. Child Maltreat. 2008 Feb;13(1):14–26. doi: 10.1177/1077559507307837. PMID: 18174345.18174345
17 Violence Prevention Alliance. The ecological framework. Geneva, Switzerland: World Health Organization; 2017. http://www.who.int/violenceprevention/approach/ecology/en/ Accessed on November 9 2017.
18 Belsky J, Vondra J. Lessons from child abuse: the determinants of parenting. In: Cicchetti D, Carlson V, eds. Child Maltreatment: Theory and Research on the Causes and Consequences of Child Abuse and Neglect. New York, NY: Cambridge University Press; 1989.
19 Daro D, McCurdy K. Interventions to prevent child maltreatment. In: Doll LS, ed Handbook of Injury and Violence Prevention Intervention. New York: Springer Publishers; 2007:137–56.
20 Wu SS, Ma CX, Carter RL, . Risk factors for infant maltreatment: a population-based study. Child Abuse Negl. 2004 Dec;28(12):1253–64. doi: 10.1016/j.chiabu.2004.07.005. PMID: 15607768.15607768
21 Gorman KS, Lourie AE, Choudhury N. Differential patterns of development: the interaction of birth weight, temperament, and maternal behavior. J Dev Behav Pediatr. 2001 Dec;22(6):366–75. PMID: 11773801.11773801
22 Sullivan PM, Knutson JF. Maltreatment and disabilities: a population-based epidemiological study. Child Abuse Negl. 2000 Oct;24(10):1257–73. PMID: 11075694.11075694
23 Crosse SB, Kaye E, Ratnofsky AC. A Report on the Maltreatment of Children with Disabilities. Washington, DC: Department of Health and Human Services, National Center on Child Abuse and Neglect; 1993.
24 Schilling RF, Schinke SP. Personal coping and social support for parents of handicapped children. Children and Youth Services Review. 1984;6(3):195–206.
25 Lynch M, Cicchetti D. An ecological-transactional analysis of children and contexts: the longitudinal interplay among child maltreatment, community violence, and children’s symptomatology. Dev Psychopathol. 1998 Spring;10(2):235–57. PMID: 9635223.9635223
26 Sampson RJ. The neighborhood context of well-being. Perspect Biol Med. 2003 Summer;46(3 Suppl):S53–64. PMID: 14563074.14563074
27 Leventhal T, Brooks-Gunn J. The neighborhoods they live in: the effects of neighborhood residence on child and adolescent outcomes. Psychol Bull. 2000 Mar;126(2):309–37. PMID: 10748645.10748645
28 Centers for Disease Control and Prevention. Child Abuse and Neglect Prevention. Atlanta, GA: Centers for Disease Control and Prevention; 2015. http://www.cdc.gov/violenceprevention/childmaltreatment. Accessed on August 3 2017.
29 Lewis TL, Kotch J, Wiley TR, . Internalizing problems: a potential pathway from childhood maltreatment to adolescent smoking. J Adolesc Health. 2011 Mar;48(3):247–52. doi: 10.1016/j.jadohealth.2010.07.004. PMID: 21338895.21338895
30 Child Welfare Information Gateway. Long-Term Consequences of Child Abuse and Neglect. Washington, DC: Child Welfare Information Gateway; 2013. https://www.childwelfare.gov/pubPDFs/long_term_consequences.pdf. Accessed on February 10, 2016.
31 Goodwin RD, Stein MB. Association between childhood trauma and physical disorders among adults in the United States. Psychol Med. 2004 Apr;34(3):509–20. PMID: 15259836.15259836
32 Power C, Pinto Pereira SM, Li L. Childhood maltreatment and BMI trajectories to mid-adult life: follow-up to age 50 y in a British birth cohort. PLoS One. 2015;10(3):e0119985. doi: 10.1371/journal.pone.0119985. PMID: 25811782.25811782
33 Gilbert R, Widom CS, Browne K, . Burden and consequences of child maltreatment in high-income countries. Lancet. 2009 Jan 03;373(9657):68–81. doi: 10.1016/S0140-6736(08)61706-7. PMID: 19056114.19056114
34 Keenan HT, Runyan DK, Marshall SW, . A population-based study of inflicted traumatic brain injury in young children. JAMA. 2003 Aug 6;290(5):621–6. doi: 10.1001/jama.290.5.621. PMID: 12902365.12902365
35 Keenan HT, Hooper SR, Wetherington CE, . Neurodevelopmental consequences of early traumatic brain injury in 3-year-old children. Pediatrics. 2007 Mar;119(3):e616–23. doi: 10.1542/peds.2006-2313. PMID: 17332181.17332181
36 Chalk R, Gibbons A, Scarupa H. The multiple dimensions of child abuse and neglect: new insights into an old problem. Child trends research brief. Washington, DC: Child Trends; 2002.
37 Caspi A, McClay J, Moffitt TE, . Role of genotype in the cycle of violence in maltreated children. Science. 2002 Aug 2;297(5582):851–4. doi: 10.1126/science.1072290. PMID: 12161658.12161658
38 Putnam FW. Ten-year research update review: child sexual abuse. J Am Acad Child Adolesc Psychiatry. 2003 Mar;42(3):269–78. doi: 10.1097/00004583-200303000-00006. PMID: 12595779.12595779
39 Chapman DP, Whitfield CL, Felitti VJ, . Adverse childhood experiences and the risk of depressive disorders in adulthood. J Affect Disord. 2004 Oct 15;82(2):217–25. doi: 10.1016/j.jad.2003.12.013. PMID: 15488250.15488250
40 Dube SR, Anda RF, Felitti VJ, . Exposure to abuse, neglect, and household dysfunction among adults who witnessed intimate partner violence as children: implications for health and social services. Violence Vict. 2002 Feb;17(1):3–17. PMID: 11991154.11991154
41 Anda RF, Chapman DP, Felitti VJ, . Adverse childhood experiences and risk of paternity in teen pregnancy. Obstet Gynecol. 2002 Jul;100(1):37–45. PMID: 12100801.12100801
42 Wiebush RG, McNulty B, Le T. Implementation of the Intensive Community-Based Aftercare Program. Washington, DC: U.S. Department of Justice, Office of Justice Programs, Office of Juvenile Justice and Delinquency Prevention; 2000.
43 Felitti VJ, Anda RF, Nordenberg D, . Relationship of childhood abuse and household dysfunction to many of the leading causes of death in adults. The Adverse Childhood Experiences (ACE) Study. Am J Prev Med. 1998 May;14(4):245–58. PMID: 9635069.9635069
44 Repetti RL, Taylor SE, Seeman TE. Risky families: family social environments and the mental and physical health of offspring. Psychol Bull. 2002 Mar;128(2):330–66. PMID: 11931522.11931522
45 Walker EA, Gelfand A, Katon WJ, . Adult health status of women with histories of childhood abuse and neglect. Am J Med. 1999 Oct;107(4):332–9. PMID: 10527034.10527034
46 National Survey of Child and Adolescent Well-Being. Child Well-Being Spotlight. Washington, DC: Administration for Children and Families, U.S. Department of Health and Human Services; 2012. http://www.acf.hhs.gov/sites/default/files/opre/youth_spotlight_v7.pdf. Accessed on February 10, 2016.
47 Oberlander SE, Wang Y, Thompson R, . Childhood maltreatment, emotional distress, and early adolescent sexual intercourse: multi-informant perspectives on parental monitoring. J Fam Psychol. 2011 Dec;25(6):885–94. doi: 10.1037/a0025423. PMID: 21928888.21928888
48 McEwen BS, Seeman T. Protective and damaging effects of mediators of stress: elaborating and testing concepts of allostasis and allostatic load. In: Adler NE, Marmot M, McEwen BS, Stewart J, eds. Socioeconomic Status and Health in Industrial Nations: Social, Psychological and Biological Pathways. Vol. 896. Annals of the New York Academy of Science; 1999:30–47.
49 Seeman TE, Singer BH, Rowe JW, . Price of adaptation-allostatic load and its health consequences. MacArthur studies of successful aging. Arch Intern Med. 1997 Oct 27;157(19):2259–68. PMID: 9343003.9343003
50 Vachon DD, Krueger RF, Rogosch FA, . Assessment of the harmful psychiatric and behavioral effects of different forms of child maltreatment. JAMA Psychiatry. 2015 Nov;72(11):1135–42. doi: 10.1001/jamapsychiatry.2015.1792. PMID: 26465073.26465073
51 Harper NS. Neglect: failure to thrive and obesity. Pediatr Clin North Am. 2014 Oct;61(5):937–57. doi: 10.1016/j.pcl.2014.06.006. PMID: 25242707.25242707
52 U.S. Department of Health and Human Services, Administration for Children and Families, Administration on Children, Youth and Families, Children’s Bureau. Child Maltreatment 2013. Washington, DC: U.S. Department of Health and Human Services, Administration for Children and Families, Administration on Children, Youth and Families, Children’s Bureau; 2015. https://www.acf.hhs.gov/sites/default/files/cb/cm2013.pdf. Accessed on February 10 2016.
53 Kotch JB, Lewis T, Hussey JM, . Importance of early neglect for childhood aggression. Pediatrics. 2008 Apr;121(4):725–31. doi: 10.1542/peds.2006-3622. PMID: 18381537.18381537
54 Hussey JM, Chang JJ, Kotch JB. Child maltreatment in the United States: prevalence, risk factors, and adolescent health consequences. Pediatrics. 2006 Sep;118(3):933–42. doi: 10.1542/peds.2005-2452. PMID: 16950983.16950983
55 Metzler M, Merrick MT, Klevens J, . Adverse childhood experiences and life opportunities: shifting the narrative. Children and Youth Services Review. 2017;72:141–9. doi: 10.1016/j.childyouth.2016.10.021.
56 National Child Traumatic Stress Network. Complex Trauma. Washington, DC: Center for Mental Health Services, Substance Abuse and Mental Health Services Administration, U.S. Department of Health and Human Services; 2016. http://www.nctsn.org/trauma-types/complex-trauma. Accessed on February 8, 2016.
57 Fang X, Brown DS, Florence CS, . The economic burden of child maltreatment in the United States and implications for prevention. Child Abuse Negl. 2012 Feb;36(2):156–65. doi: 10.1016/j.chiabu.2011.10.006. PMID: 22300910.22300910
58 Wulczyn F. Epidemiological perspectives on maltreatment prevention. Future Child. 2009 Fall;19(2):39–66. PMID: 19719022.19719022
59 Kelley ML, Lawrence HR, Milletich RJ, . Modeling risk for child abuse and harsh parenting in families with depressed and substance-abusing parents. Child Abuse Negl. 2015 May;43:42–52. doi: 10.1016/j.chiabu.2015.01.017. PMID: 25724658.25724658
60 Molnar BE, Buka SL, Brennan RT, . A multilevel study of neighborhoods and parent-to-child physical aggression: results from the project on human development in Chicago neighborhoods. Child Maltreat. 2003 May;8(2):84–97. PMID: 12735711.12735711
61 Clarke J, Stein MD, Sobota M, . Victims as victimizers: physical aggression by persons with a history of childhood abuse. Arch Intern Med. 1999 Sep 13;159(16):1920–4. PMID: 10493322.10493322
62 DiLillo D, Tremblay GC, Peterson L. Linking childhood sexual abuse and abusive parenting: the mediating role of maternal anger. Child Abuse Negl. 2000 Jun;24(6):767–79. PMID: 10888017.10888017
63 Sedlak AJ, Broadhurst DD. The national incidence study of child abuse and neglect. Washington, DC: U.S. Department of Health and Human Services; 1996.
64 Bishop SJ, Leadbeater BJ. Maternal social support patterns and child maltreatment: comparison of maltreating and nonmaltreating mothers. Am J Orthopsychiatry. 1999 Apr;69(2):172–81. PMID: 10234383.10234383
65 Centers for Disease Control and Prevention. Children Benefit When Parents Have Safe, Stable, Nurturing Relationships. Atlanta, GA: Centers for Disease Control and Prevention. http://www.cdc.gov/violenceprevention/pdf/ssnrs-for-parents.pdf. Accessed on February 10, 2016.
66 U.S. Department of Health and Human Services. Preventing Child Maltreatment and Promoting Well-Being: A Network for Action 2013 Resource Guide. Washington, DC: U.S. Department of Health and Human Service, Administration for Children and Families; n.d.
67 Schofield TJ, Lee RD, Merrick MT. Safe, stable, nurturing relationships as a moderator of intergenerational continuity of child maltreatment: a meta-analysis. J Adolesc Health. 2013 Oct;53:(4 Suppl):S32–8. doi: 10.1016/j.jadohealth.2013.05.004. PMID: 24059937.24059937
68 MacMillan HL, Canadian Task Force on Preventive Health C. Preventive health care, 2000 update: prevention of child maltreatment. CMAJ. 2000 Nov 28;163(11):1451–8. PMID: 11192650.11192650
69 Kodner C, Wetherton A. Diagnosis and management of physical abuse in children. Am Fam Physician. 2013 Nov 15;88(10):669–75. PMID: 24364482.24364482
70 Centers for Disease Control and Prevention. Guide to Community Preventive Services. Violence Prevention: Early Childhood Home Visitation. Atlanta, GA: Centers for Disease Control and Prevention; 2010.
71 Flaherty EG, Stirling J, Jr., American Academy of Pediatrics. Committee on Child A, . Clinical report-the pediatrician’s role in child maltreatment prevention. Pediatrics. 2010 Oct;126(4):833–41. PMID: 20945525.20945525
72 Christian CW, Committee on Child Abuse and Neglect, American Academy of Pediatrics. The evaluation of suspected child physical abuse. Pediatrics. 2015 May;135(5):e1337–54. doi: 10.1542/peds.2015-0356. PMID: 25917988.25917988
73 Duffee JH, Mendelsohn AL, Kuo AA, . Early childhood home visiting. Pediatrics. 2017 Sep;140(3). doi: 10.1542/peds.2017-2150. PMID: 28847981.28847981
74 Flaherty EG, Sege R, Binns HJ, . Health care providers’ experience reporting child abuse in the primary care setting. Pediatric Practice Research Group. Arch Pediatr Adolesc Med. 2000 May;154(5):489–93. PMID: 10807301.10807301
75 Flaherty EG, Jones R, Sege R, . Telling their stories: primary care practitioners’ experience evaluating and reporting injuries caused by child abuse. Child Abuse Negl. 2004 Sep;28(9):939–45. doi: 10.1016/j.chiabu.2004.03.013. PMID: 15450760.15450760
76 Kolko DJ, Cohen JA, Mannarino AP, . Community treatment of child sexual abuse: a survey of practitioners in the National Child Traumatic Stress Network. Adm Policy Ment Health. 2009 Jan;36(1):37–49. doi: 10.1007/s10488-008-0180-0. PMID: 18568396.18568396
77 Bilukha O, Hahn RA, Crosby A, . The effectiveness of early childhood home visitation in preventing violence: a systematic review. Am J Prev Med. 2005 Feb;28(2 Suppl 1):11–39. doi: 10.1016/j.amepre.2004.10.004. PMID: 15698746.15698746
78 Segal L, Sara Opie R, Dalziel K. Theory! The missing link in understanding the performance of neonate/infant home-visiting programs to prevent child maltreatment: a systematic review. Milbank Q. 2012 Mar;90(1):47–106. doi: 10.1111/j.1468-0009.2011.00655.x [doi]. PMID: 22428693.22428693
79 Mikton C, Butchart A. Child maltreatment prevention: a systematic review of reviews. Bull World Health Organ. 2009 May;87(5):353–61. PMID: 19551253.19551253
80 Rucker G, Schwarzer G, Carpenter JR, . Undue reliance on I(2) in assessing heterogeneity may mislead. BMC Med Res Methodol. 2008;8:79. doi: 10.1186/1471-2288-8-79. PMID: 19036172.19036172
81 United Nations Development Programme. Human Development Report 2015: Work for Human Development. Table 1: Human Development Index and its components. New York, NY: United Nations Development Programme; n.d. http://hdr.undp.org/en/composite/HDI. Accessed on July 18 2017.
82 Higgins JP, Green S. Cochrane Handbook for Systematic Reviews of Interventions. The Cochrane Collaboration; 2011. www.handbook.cochrane.org. Accessed on 24 Aug 2016.
83 U.S. Preventive Services Task Force. Methods and Processes. Rockville, MD: U.S. Preventive Services Task Force; 2015. http://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes. Accessed on 18 Jul 2018.
84 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
85 International Society for Clinical Densitometry. 2015 ISCD Official Positions - Adult. Middletown, CT: International Society for Clinical Densitometry, Inc; 2015. http://www.iscd.org/official-positions/2015-iscd-official-positions-adult/ Accessed on 10 Aug 2016.
86 Comprehensive Meta Analysis. Version 3.3.070. Englewood, NJ; 2014.
87 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
88 Higgins JP, Thompson SG, Deeks JJ, . Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 6;327(7414):557–60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
89 Siegel E, Bauman KE, Schaefer ES, . Hospital and home support during infancy: impact on maternal attachment, child abuse and neglect, and health care utilization. Pediatrics. 1980 Aug;66(2):183–90. PMID: 7402803.7402803
90 Robling M, Bekkers M-J, Bell K, . Effectiveness of a nurse-led intensive home-visitation programme for first-time teenage mothers (Building Blocks): a pragmatic randomised controlled trial. The Lancet. 387(10014):146–55. doi: 10.1016/S0140-6736(15)00392-X.
91 Duggan A, Caldera D, Rodriguez K, . Impact of a statewide home visiting program to prevent child abuse. Child Abuse Negl. 2007 Aug;31(8):801–27. doi: 10.1016/j.chiabu.2006.06.011. PMID: 17822764.17822764
92 Caldera D, Burrell L, Rodriguez K, . Impact of a statewide home visiting program on parenting and on child health and development. Child Abuse Negl. 2007 8//;31(8):829–52. doi: 10.1016/j.chiabu.2007.02.008.17822765
93 DuMont K, Mitchell-Herzfeld S, Greene R, . Healthy Families New York (HFNY) randomized trial: effects on early child abuse and neglect. Child Abuse Negl. 2008 Mar;32(3):295–315. doi: 10.1016/j.chiabu.2007.07.007. PMID: 18377991.18377991
94 Dumont K, Kirkland K, Mitchell-Herzfeld S, . A randomized trial of Healthy Families New York (HFNY): Does home visiting prevent child maltreatment. This research was supported by Award No: 2006-MU-MU-0002 awarded by the National Institute of Justice, U.S. Department of Justice and prepared by The New York State Office of Children & Family Services and The University of Albany, State University of New York. Rensselaer, NY: 2010.
95 Sadler LS, Slade A, Close N, . Minding the Baby: Enhancing reflectiveness to improve early health and relationship outcomes in an interdisciplinary home visiting program. Infant Ment Health J. 2013 Sep 01;34(5):391–405. doi: 10.1002/imhj.21406. PMID: 24049219.24049219
96 Kitzman H, Olds DL, Henderson CR, Jr., . Effect of prenatal and infancy home visitation by nurses on pregnancy outcomes, childhood injuries, and repeated childbearing. A randomized controlled trial. JAMA. 1997 Aug 27;278(8):644–52. PMID: 9272896.9272896
97 Olds DL, Sadler L, Kitzman H. Programs for parents of infants and toddlers: recent evidence from randomized trials. J Child Psychol Psychiatry. 2007 Mar-Apr;48(3-4):355–91. doi: 10.1111/j.1469-7610.2006.01702.x. PMID: 17355402.17355402
98 Olds DL, Henderson CR, Jr., Chamberlin R, . Preventing child abuse and neglect: a randomized trial of nurse home visitation. Pediatrics. 1986 Jul;78(1):65–78. PMID: 2425334.2425334
99 Olds DL, Henderson CR, Kitzman H. Does prenatal and infancy nurse home visitation have enduring effects on qualities of parental caregiving and child health at 25 to 50 months of life? Pediatrics. 1994;39(1):89–98.
100 Olds DL, Eckenrode J, Henderson CR, Jr., . Long-term effects of home visitation on maternal life course and child abuse and neglect. Fifteen-year follow-up of a randomized trial. JAMA. 1997 Aug 27;278(8):637–43. PMID: 9272895.9272895
101 Eckenrode J, Ganzel B, Henderson CR, Jr., . Preventing child abuse and neglect with a program of nurse home visitation: the limiting effects of domestic violence. JAMA. 2000 Sep 20;284(11):1385–91. PMID: 10989400.10989400
102 Zielinski DS, Eckenrode J, Olds DL. Nurse home visitation and the prevention of child maltreatment: Impact on the timing of official reports. Dev Psychopathol. 2009;21(02):441–53.19338692
103 Lam WK, Fals-Stewart W, Kelley ML. Parent training with behavioral couples therapy for fathers’ alcohol abuse: effects on substance use, parental relationship, parenting, and CPS involvement. Child Maltreat. 2009 Aug;14(3):243–54. doi: 10.1177/1077559509334091. PMID: 19502478.19502478
104 Barlow J, Davis H, McIntosh E, . Role of home visiting in improving parenting and health in families at risk of abuse and neglect: results of a multicentre randomised controlled trial and economic evaluation. Arch Dis Child. 2007 Mar;92(3):229–33. doi: 10.1136/adc.2006.095117. PMID: 17068074.17068074
105 McIntosh E, Barlow J, Davis H, . Economic evaluation of an intensive home visiting programme for vulnerable families: a cost-effectiveness analysis of a public health intervention. J Public Health (Oxf). 2009 Sep;31(3):423–33. doi: 10.1093/pubmed/fdp047. PMID: 19497944.19497944
106 Bugental DB, Schwartz A. A cognitive approach to child mistreatment prevention among medically at-risk infants. Dev Psychol. 2009 Jan;45(1):284–8. doi: 10.1037/a0014031. PMID: 19210009.19210009
107 Easterbrooks MA, Bartlett JD, Raskin M, . Limiting home visiting effects: maternal depression as a moderator of child maltreatment. Pediatrics. 2013 Nov;132: Suppl 2:S126–33. doi: 10.1542/peds.2013-1021K. PMID: 24187114.24187114
108 Fergusson DM, Grant H, Horwood LJ, . Randomized trial of the Early Start program of home visitation. Pediatrics. 2005 Dec;116(6):e803–9. doi: 10.1542/peds.2005-0948. PMID: 16322138.16322138
109 Fergusson DM, Boden JM, Horwood LJ. Nine-year follow-up of a home-visitation program: a randomized trial. Pediatrics. 2013 Feb;131(2):297–303. doi: 10.1542/peds.2012-1612. PMID: 23359575.23359575
110 Larson CP. Efficacy of prenatal and postpartum home visits on child health and development. Pediatrics. 1980;66(2):191–7.7402804
111 Silovsky JF, Bard D, Chaffin M, . Prevention of child maltreatment in high-risk rural families: A randomized clinical trial with child welfare outcomes. Children and Youth Services Review. 2011 8//;33(8):1435–44. doi: 10.1016/j.childyouth.2011.04.023.
112 Brayden RM, Altemeier WA, Dietrich MS, . A prospective study of secondary prevention of child maltreatment. J Pediatr. 1993 Apr;122(4):511–6. PMID: 8463893.8463893
113 Brooten D, Kumar S, Brown LP, . A randomized clinical trial of early hospital discharge and home follow-up of very-low-birth-weight infants. N Engl J Med. 1986 Oct 9;315(15):934–9. doi: 10.1056/NEJM198610093151505. PMID: 3531852.3531852
114 Finello KM, Litton KM, deLemos R, . Very low birth weight infants and their families during the first year of life: comparisons of medical outcomes based on after care services. J Perinatol. 1997;18(5):365–71.
115 Guyer B, Barth M, Bishai D, . Healthy Steps for Young Children Program and National Evaluation Overview. Baltimore, MD: Women’s and Children’s Health Policy Center, Department of Population and Family Health Sciences, John Hopkins Bloomberg School of Public Health; 2003. http://www.jhsph.edu/research/centers-and-institutes/womens-and-childrens-health-policy-center/projects/Healthy_Steps/index.html. Accessed on July 24 2017.
116 Minkovitz CS, Strobino D, Mistry KB, . Healthy Steps for Young Children: sustained results at 5.5 years. Pediatrics. 2007;120(3):e658–e68.17766506
117 Lowell DI, Carter AS, Godoy L, . A randomized controlled trial of Child FIRST: a comprehensive home-based intervention translating research into early childhood practice. Child Dev. 2011 Jan-Feb;82(1):193–208. doi: 10.1111/j.1467-8624.2010.01550.x [doi]. PMID: 21291437.21291437
118 Marcenko MO, Spence M. Home visitation services for at-risk pregnant and postpartum women: a randomized trial. Am J Orthopsychiatry. 1994 Jul;64(3):468–78. PMID: 7977669.7977669
119 Quinlivan JA, Box H, Evans SF. Postnatal home visits in teenage mothers: a randomised controlled trial. The Lancet. 2003;361(9361):893–900.
120 Wiggins M, Oakley A, Roberts I, . The Social Support and Family Health Study: a randomised controlled trial and economic evaluation of two alternative forms of postnatal support for mothers living in disadvantaged inner-city areas. Health Technol Assess. 2004 Aug;8(32):iii, ix–x, 1–120. PMID: 15298823.15298823
121 Wiggins M, Oakley A, Roberts I, . Postnatal support for mothers living in disadvantaged inner city areas: a randomised controlled trial. J Epidemiol Community Health. 2005 Apr;59(4):288–95. doi: 10.1136/jech.2004.021808. PMID: 15767382.15767382
122 Kelly MP, Noyes J, Kane RL, . AHRQ series on complex intervention systematic reviews - paper 2: defining complexity, formulating scope and questions. J Clin Epidemiol. 2017 Jun 29. doi: 10.1016/j.jclinepi.2017.06.012. PMID: 28720514.28720514
123 Frontiers of Innovation. Frontiers of Innovation Portfolio: Programs at a Glance. 2017. http://developingchild.harvard.edu/foi-portfolio/. Accessed on August 10 2017.
124 Krug EG, Dahlberg LL, Mercy JA, . Chapter 3: Child abuse and neglect by parents and other caregivers. World Report on Violence and Health. Geneva, Switzerland: World Health Organization; 2002:57–86.
125 Simon Fraser University. BC Healthy Connections Project (BCHCP). Bethesda, MD: National Library of Medicine; 2012.
126 Bonuck K. Birth to Three: a pragmatic clinical trial for child maltreatment prevention. Albert Einstein College of Medicine, Department of Family and Social Medicine. 2012.
127 Boston Medical Center. A Pilot Intervention With Families of Children With Special Health Care Needs. Bethesda, MD: National Library of Medicine; 2016.
128 Murphy A, Bonuck K, Meissner P, . A Pragmatic Clinical Trial For Child Maltreatment Prevention. Albert Einstein College of Medicine. R40MC23629. Bronx, NY: April 30 2016. https://media.mchtraining.net/research/documents/finalreports/bonuck_r40mc23629_finalreport.pdf.
129 Child Welfare Information Gateway. Definitions of Child Abuse and Neglect. Washington, DC: U.S. Department of Health and Human Services, Children’s Bureau; 2014. https://www.childwelfare.gov/pubPDFs/define.pdf. Accessed on August 3 2017.
130 Child Welfare Information Gateway. What is child abuse and neglect? Recognizing the signs and symptoms. Washington, DC: U.S. Department of Health and Human Services, Children’s Bureau; 2013. https://www.childwelfare.gov/pubpdfs/whatiscan.pdf. Accessed on January 19, 2016.
131 Kelleher K, Gardner W, Coben J, . Co-Occurring Intimate Partner Violence and Child Maltreatment: Local Policies/Practices and Relationships to Child Placement, Family Services, and Residence. Final report to the National Institute of Justice; 2006.
132 Murphy S, Orkow B, M. Nicola R. Prenatal prediction of child abuse and neglect: A prospective study. Child Abuse Negl. 1985 1985/01/01/;9(2):225–35. doi: 10.1016/0145-2134(85)90015-8.4005663
133 Altemeier WA, O’Connor S, Vietze P, . Prediction of child abuse: A prospective study of feasibility. Child Abuse Negl. 1984 1984/01/01/;8(4):393–400. doi: 10.1016/0145-2134(84)90020-6.6542812
134 Barth RP. An experimental evaluation of in-home child abuse prevention services. Child Abuse Negl. 1991;15(4):363–75. PMID: 1959070.1959070
135 Gray JD, Cutler CA, Dean JG, . Prediction and prevention of child abuse. Semin Perinatol. 1979 Jan;3(1):85–90. PMID: 482971.482971
136 Gray JD, Cutler CA, Dean JG, . Prediction and prevention of child abuse and neglect. Child Abuse Negl. 1977;1(1):45–58.
137 Milner JS, Gold RG, Ayoub C, . Predictive validity of the child abuse potential inventory. J Consult Clin Psychol. 1984;52(5):879.6501673
138 Cerny JE, Inouye J. Utilizing the child abuse potential inventory in a community health nursing prevention program for child abuse. J Community Health Nurs. 2001 Winter;18(4):199–211. doi: 10.1207/S15327655JCHN1804_01. PMID: 11775554.11775554
139 Johnson WL. The validity and utility of the California Family Risk Assessment under practice conditions in the field: a prospective study. Child Abuse Negl. 2011 Jan;35(1):18–28. doi: 10.1016/j.chiabu.2010.08.002. PMID: 21316761.21316761
140 Kemp AM, Hollen L, Rea D, . A clinical prediction tool (CPT) to identify maltreatment in children with burns and scalds. Arch Dis Child. 2015;100((Kemp A.M.; Pawlik M.C.; Nuttall D.; Maguire S.) Institute of Primary Care and Public Health, Cardiff University, Cardiff, United Kingdom):A19.
141 Anderson CL. The parenting profile assessment: screening for child abuse. Appl Nurs Res. 1993 Feb;6(1):31–8. PMID: 8439176.8439176
142 Sittig JS, Uiterwaal CS, Moons KG, . Value of systematic detection of physical child abuse at emergency rooms: a cross-sectional diagnostic accuracy study. BMJ Open. 2016 Mar 22;6(3):e010788. doi: 10.1136/bmjopen-2015-010788. PMID: 26978697.26978697
143 Hoft M, Haddad L. Screening Children for Abuse and Neglect: A Review of the Literature. J Forensic Nurs. 2017 Jan/Mar;13(1):26–34. doi: 10.1097/jfn.0000000000000136. PMID: 28192770.28212197
144 Korfmacher J. The Kempe Family Stress Inventory: a review. Child Abuse Negl. 2000 Jan;24(1):129–40. PMID: 10660015.10660015
145 Duggan AK, McFarlane EC, Windham AM, . Evaluation of Hawaii’s Healthy Start Program. Future Child. 1999 Spring-Summer;9(1):66–90; discussion 177-8. PMID: 10414011.10414011
146 Duggan A, McFarlane E, Fuddy L, . Randomized trial of a statewide home visiting program: impact in preventing child abuse and neglect. Child Abuse Negl. 2004 Jun;28(6):597–622. doi: 10.1016/j.chiabu.2003.08.007. PMID: 15193851.15193851
147 Dubowitz H, Lane WG, Semiatin JN, . The SEEK model of pediatric primary care: can child maltreatment be prevented in a low-risk population? Acad Pediatr. 2012 Jul-Aug;12(4):259–68. doi: 10.1016/j.acap.2012.03.005. PMID: 22658954.22658954
148 Dubowitz H, Feigelman S, Lane W, . Pediatric primary care to help prevent child maltreatment: the Safe Environment for Every Kid (SEEK) Model. Pediatrics. 2009 Mar;123(3):858–64. doi: 10.1542/peds.2008-1376. PMID: 19255014.19255014
149 Kruizinga I, Jansen W, van Sprang NC, . The Effectiveness of the BITSEA as a Tool to Early Detect Psychosocial Problems in Toddlers, a Cluster Randomized Trial. PLoS One. 2015;10(9):e0136488. doi: 10.1371/journal.pone.0136488. PMID: 26383910.26383910
150 Brownell MD, Chartier M, Santos R, . Evaluation of a newborn screen for predicting out-of-home placement. Child Maltreat. 2011 Nov;16(4):239–49. doi: 10.1177/1077559511422942. PMID: 22007033.22007033
151 Armstrong KL, Fraser JA, Dadds MR, . A randomized, controlled trial of nurse home visiting to vulnerable families with newborns. J Paediatr Child Health. 1999 Jun;35(3):237–44. PMID: 10404442.10404442
152 McCurdy K. Risk assessment in child abuse prevention programs. Soc Work Res. 1995;19(2):77–87.
153 Olds D, Henderson CR, Jr., Kitzman H, . Effects of prenatal and infancy nurse home visitation on surveillance of child maltreatment. Pediatrics. 1995 Mar;95(3):365–72. PMID: 7862474.7862474
154 Olds DL, Kitzman H, Hanks C, . Effects of nurse home visiting on maternal and child functioning: age-9 follow-up of a randomized trial. Pediatrics. 2007 Oct;120(4):e832–45. doi: 10.1542/peds.2006-2111. PMID: 17908740.17908740
155 Taylor JE, Harvey ST. A meta-analysis of the effects of psychotherapy with adults sexually abused in childhood. Clin Psychol Rev. 2010 Aug;30(6):749–67. doi: 10.1016/j.cpr.2010.05.008. PMID: 20579790.20579790
156 Stevens-Simon C, Barrett J. A comparison of the psychological resources of adolescents at low and high risk of mistreating their children. J Pediatr Health Care. 2001 Nov-Dec;15(6):299–303. doi: 10.1067/mph.2001.114385. PMID: 11717686.11717686
157 Black MM, Nair P, Kight C, . Parenting and early development among children of drug-abusing women - effects of home intervention. Pediatrics. 1994 Oct;94(4):440–8. PMID: WOS:A1994PK84000005.7936850
158 Bugental DB, Ellerson PC, Lin EK, . A cognitive approach to child abuse prevention. J Fam Psychol. 2002 Sep;16(3):243–58. PMID: 12238408.12238408
159 Duggan A, Windham A, McFarlane E, . Hawaii’s healthy start program of home visiting for at-risk families: evaluation of family identification, family engagement, and service delivery. Pediatrics. 2000 Jan;105(1 Pt 3):250–9. PMID: 10617732.10617732
160 El-Mohandes AA, Katz KS, El-Khorazaty MN, . The effect of a parenting education program on the use of preventive pediatric health care services among low-income, minority mothers: a randomized, controlled study. Pediatrics. 2003 Jun;111(6 Pt 1):1324–32. PMID: 12777548.12777548
161 Fraser JA, Armstrong KL, Morris JP, . Home visiting intervention for vulnerable families with newborns: follow-up results of a randomized controlled trial. Child Abuse Negl. 2000 Nov;24(11):1399–429. PMID: 11128173.11128173
162 El-Mohandes AA, Kiely M, Blake SM, . An intervention to reduce environmental tobacco smoke exposure improves pregnancy outcomes. Pediatrics. 2010 Apr;125(4):721–8. doi: 10.1542/peds.2009-1809. PMID: 20211945.20211945
163 Kiely M, El-Mohandes AA, El-Khorazaty MN, . An integrated intervention to reduce intimate partner violence in pregnancy: a randomized controlled trial. Obstet Gynecol. 2010 Feb;115(2 Pt 1):273–83. doi: 10.1097/AOG.0b013e3181cbd482. PMID: 20093899.20093899
164 Olds DL, Kitzman H, Cole R, . Effects of nurse home-visiting on maternal life course and child development: age 6 follow-up results of a randomized trial. Pediatrics. 2004 Dec;114(6):1550–9. doi: 10.1542/peds.2004-0962. PMID: 15574614.15574614
165 Dawson P, van Doorninck WJ, Robinson JL. Effects of home-based, informal social support on child health. J Dev Behav Pediatr. 1989 Apr;10(2):63–7. PMID: 2708538.2708538
166 Flynn L. The adolescent parenting program: improving outcomes through mentorship. Public Health Nurs. 1999 Jun;16(3):182–9. PMID: 10388335.10388335
167 Leventhal JM, Pew MC, Berg AT, . Use of health services by children who were identified during the postpartum period as being at high risk of child abuse or neglect. Pediatrics. 1996 Mar;97(3):331–5. PMID: 8604265.8604265
168 McGuigan WM, Vuchinich S, Pratt CC. Domestic violence, parents’ view of their infant, and risk for child abuse. J Fam Psychol. 2000 Dec;14(4):613–24. PMID: 11132484.11132484
169 Katzev A, Pratt C, Henderson T, . Oregon’s Healthy Start Effort: 1997-98 Status Report. Corvalis, OR: Oregon State University Family Policy Program; 1999.
170 Center on Child Abuse Prevention Research. Intensive home visitation: A randomized trial, follow-up, and risk assessment study of Hawaii’s Healthy Start program. Final report prepared for the National Center on Child Abuse and Neglect, United States Department of Health and Human Services (NCCAN Grant #90-CA-1511). Chicago, IL: National Committee to Prevent Child Abuse, Center on Child Abuse Prevention Research; June 1996.
171 Koniak-Griffin D, Verzemnieks IL, Anderson NL, . Nurse visitation for adolescent mothers: two-year infant health and maternal outcomes. Nurs Res. 2003 Mar-Apr;52(2):127–36. PMID: 12657988.12657988
172 DePanfilis D, Dubowitz H. Family connections: a program for preventing child neglect. Child Maltreat. 2005 May;10(2):108–23. doi: 10.1177/1077559505275252. PMID: 15798007.15798007
173 Hardy JB, Streett R. Family support and parenting education in the home: an effective extension of clinic-based preventive health care services for poor children. J Pediatr. 1989;115(6):927–31.2585229
174 Infante-Rivard C, Filion G, Baumgarten M, . A public health home intervention among families of low socioeconomic status. Child Health Care. 1989;18(2):102–7.
175 Koniak-Griffin D, Anderson NL, Brecht M-L, . Public health nursing care for adolescent mothers: impact on infant health and selected maternal outcomes at 1 year postbirth. J Adolesc Health. 2002;30(1):44–54.
176 Mejdoubi J, van den Heijkant SC, van Leerdam FJ, . The effect of VoorZorg, the Dutch nurse-family partnership, on child maltreatment and development: a randomized controlled trial. PLoS One. 2015;10(4):e0120182. doi: 10.1371/journal.pone.0120182. PMID: 25830242.25830242
177 Norr KF, Crittenden KS, Lehrer EL, . Maternal and infant outcomes at one year for a nurse-health advocate home visiting program serving African Americans and Mexican Americans. Public Health Nurs. 2003 May-Jun;20(3):190–203. PMID: 12716399.12716399
178 Paradis HA, Sandler M, Manly JT, . Building healthy children: evidence-based home visitation integrated with pediatric medical homes. Pediatrics. 2013 Nov;132: Suppl 2:S174–9. doi: 10.1542/peds.2013-1021R. PMID: 24187121.24187121
179 Wagner MM, Clayton SL. The Parents as Teachers program: Results from two demonstrations. The Future of Children. 1999:91–115.10414012
180 Barnes‐Boyd C, Fordham Norr K, Nacion KW. Promoting infant health through home visiting by a nurse‐managed community worker team. Public Health Nurs. 2001;18(4):225–35.11468062
181 Nelson H, Nygren P, McInerney Y. Screening for Family and Intimate Partner Violence [Internet]. U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Rockville, MD: Agency for Healthcare Research and Quality; March 2004. PMID: 2072212420722124
182 Kan ML, Feinberg ME. Can a family-focused, transition-to-parenthood program prevent parent and partner aggression among couples with young children? Violence Vict. 2014;29(6):967–80. PMID: 25905139.25905139
183 Guterman NB, Tabone JK, Bryan GM, . Examining the effectiveness of home-based parent aide services to reduce risk for physical child abuse and neglect: six-month findings from a randomized clinical trial. Child Abuse Negl. 2013 Aug;37(8):566–77. doi: 10.1016/j.chiabu.2013.03.006. PMID: 23623622.23623622
184 LeCroy CW, Krysik J. Randomized trial of the healthy families Arizona home visiting program. Children and Youth Services Review. 2011 10//;33(10):1761–6. doi: 10.1016/j.childyouth.2011.04.036.
185 Nair P, Schuler ME, Black MM, . Cumulative environmental risk in substance abusing women: early intervention, parenting stress, child abuse potential and child development. Child Abuse Negl. 2003;27(9):997–1017.14550328
186 Reedtz C, Handegard BH, Morch WT. Promoting positive parenting practices in primary pare: outcomes and mechanisms of change in a randomized controlled risk reduction trial. Scand J Psychol. 2011 Apr;52(2):131–7. doi: 10.1111/j.1467-9450.2010.00854.x. PMID: 21121925.21121925