# Acknowledgments

The authors acknowledge the following individuals for their contributions to this project: Justin Mills, MD, MPH, AHRQ Medical Officer; Iris Mabry-Hernandez, MD, MPH, AHRQ Medical Officer; Tracy Wolff, MD, MPH, AHRQ Associate Scientific Director; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; expert reviewers Charles Wilson, MSSW, Chadwick Center for Children and Families at Rady Children’s Hospital-San Diego; M. Denise Dowd, MD, MPH, Division of Emergency Medicine at the University of Missouri-Kansas City; Joanne N. Wood, MD, MSHP, Perelman School of Medicine at the University of Pennsylvania; Ken Epstein, PhD, LCSW, San Francisco Department of Public Health; Ron Prinz, PhD, Parenting and Family Research Center at the University of South Carolina; federal partner reviewers Beverly Fortson, PhD, and Joanne Klevens, MD, PhD, MPH from the National Center for Injury Prevention and Control at the Centers for Disease Control and Prevention; one anonymous reviewer; Research Affiliates EPC and RTI International–University of North Carolina EPC staff Lynn Whitener, DrPH; Carol Woodell, BSPH; Rachel Weber, PhD; Catherine A. Grodensky, MPH; Sharon Barrell, MA; and Loraine Monroe.