# Chapter 4 Discussion

This chapter begins with a summary of review findings for each KQ; Table 2 provides additional details. We then present limitations of the evidence and our update review and end with conclusions and recommendations for future research.

## Summary of Review Findings

### Benefits of Interventions (Key Question 1)

The evidence on the effect of interventions that are feasible in or referable from primary care settings on short-term outcomes for interventions to prevent child maltreatment, reports to CPS, ED visits, and hospitalizations suggests no benefit (Table 3). Long-term results of the same outcomes are not consistent. Results from the Nurse Family Partnership generally demonstrate benefit and the other trials do not. Other systematic reviews also found inconsistent evidence of benefits for trials other than the Nurse Family Partnership.^78^ At or beyond the 3-year followup, two trials reported fewer CPS reports,^100,^ ^101,^ ^117^ and one did not.^93,^ ^94^ One^99^ of two trials^99,^ ^116^ reporting on ED visits at or beyond the 4-year followup found lower rates of ED visits in the intervention arm. Other concerns with long-term outcomes include risks of contamination or unmeasured co-interventions. Additionally, interpretation of some outcomes can be challenging. Lower rates of all-cause ED visits or hospitalization may represent changes in patterns of health care utilization as a result of the intervention rather than lower rates of abuse or neglect. Sensitivity analyses that include poor-quality studies did not change our conclusions (Appendix F2). The evidence was also inconclusive for other outcomes, based primarily on the limited number of trials reporting on each outcome and lack of statistically significant results. These include injuries, failure to thrive, failure to immunize, internalizing and externalizing behavior symptoms, school attendance, and other measures of abuse or neglect. The evidence also suggests no benefit for removal of the child from the home, child development, school performance, and prevention of death.

Table 3 Summary of Evidence of Interventions to Prevent Child Maltreatment

Key Question | Population, Intervention | No. of Studies; No. of Observations | Summary of Findings by Outcome | Consistency/ Precision | Reporting Bias | Overall Quality of Studies | Body of Evidence Limitations | EPC Assessment of Strength of Evidence: For Outcome | Applicability
KQ 1: Reports to CPS | Caregivers of children at risk of maltreatment | 14; 4,958 | CPS reports at or within 1 year of trial completion: OR, 0.94, 95% CI, 0.72 to 1.23, I^2^: 6.3%, 11.1% vs. 11.8% (k=10, 2,434 participants) Mixed results for long-term followup^*^ | Consistent/imprecise short-term outcomes; inconsistent/imprecise for long-term outcomes | No evidence of reporting bias | Fair | Heterogeneity iacross studies in type of intervention | Low for no benefit for short-term outcomes, insufficient for long-term outcomes | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Removal of the child from home | Infants/toddlers age [underlined: <]3 years | 5; 885 | Removals 0–3 years: 11/313 (3.51%) vs. 11/296 (3.71%); OR, 1.09; 95% CI, 0.16 to 7.28, I^2^:61.8% (k=4, 609 participants) Removals at birth (for intervention started in pregnancy) in one study: calculated OR,^†^ 1.55; 95% CI, 0.61 to 3.94, 225 participants | Inconsistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity across studies in timing of outcome | Low for no benefit | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Other measures of abuse or neglect | Caregivers (mothers or families) | 2; 461 | Abuse:^ǂ^ 13/141 (9.2%) vs. 8/122 (6.6%); RR, 1.4, 95% CI, 0.58 to 3.62; k=1, 263 participants Neglect:^§^ 15/141 (10.6%) vs. 5/122 (4.1%); RR, 2.79, 95% CI, 0.98 to 7.91; 1 trial, 263 participants Significantly higher safety scores in the intervention arm; 1 trial, 147 participants | Inconsistent/imprecuse | No evidence of reporting bias | Fair | Heterogeneity across studies in outcome measurest | Insufficient | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Injuries with a high specificity for abuse | Adolescent mothers | 1; 136 | Nonaccidental injuries: 0/64 (0) vs. 1/71 (1.4%), calculated RR: 0.37, 95% CI, 0.015 to 8.91 | Consistency unknown (single trial)/imprecise | No evidence of reporting bias | Fair | Single small trial | Insufficient | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Visits to the ER | Children | 11; 5,732 | 2 of 7 studies reported a statistically significant difference in mean number of all-cause ED visits the first 2 years of followup; all other studies report results that are not statistically significant^ǁ^ 1 of 2 studies reported statistically significant results at the 2- to 4-year followup for each of the following: mean number of all-cause ED vists; mean number of EDR visits for accidents, injuries, and ingestions; and number of children seen for accidents or injuries; 2 studies found no differences for number of children seen in the ER; 1 study found no difference in the proportion of children seen for injuries and ingestions 1 of 2 studies reported statistically significant differences at long-term followup | Inconsistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity across studies in outcome measures | Low for no benefit for short-term outcomes, insufficient for long-term outcomes | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1 Hospitaliza-tion | Infants | 12; 5,491 | 1 of 5 studies showed a reduction in number of children with all-cause hospitalization, but only for 1 of 4 outcome measures 1 of 2 studies found a lower mean number of hospital days 1 trial found lower overall rates of hospital admission for unintentional injury at a 9-year followup All other outcomes not statistically significantly different^¶^ | Consistent/imprecise for results under 3 years; inconsistent/imprecise for long-term followup | No evidence of reporting bias | Fair | Heterogeneity outcome measures; each outcome/timing only presented in a single study | Low strength of evidence of no benefit | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Failure to thrive | Infants | 1; 79 | 0% (0/39) vs. 2.5% (1/40), RR: 0.34, 95% CI, 0.01 to 8.14 | Consistency unknown (single trial)/imprecise | No evidence of reporting bias | Fair | Single small trial | Insufficient | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Failure to immunize | Adolescent mothers | 1; 136 | No vaccinations at 6 months: 4/71 (5.6%) vs. 9/65 (13.8%), calculated RR: 0.49, 95% CI, 0.16 to 1.52 | Consistency unknown (single trial)/imprecise | No evidence of reporting bias | Fair | Single small trial | Insufficient | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1 Internalizing and externalizing behavior symptoms | Caregivers of children at risk of maltreatment | 6; 5,529 | 3 of 6 trials reported reductions in behavior difficulties^#^ Other outcomes are not statistically significantly different^**^ | Inconsistent/imprecise | No evidence of reporting bias | Fair | Small number of trials; heterogeneity of outcome measures | Insufficient | Home-based intervention targeting high-risk families may be effective in decreasing behavior problems
KQ 1: Other social, emotional, and develop-mental outcomes | Infants/toddlers [underlined: <3] years of age | 4, 3,965 children | 0 of 5 studes reported statistically signfiicant differences on a variety of social, emotional, and developmental measures^††^ | Consistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity outcome measures; each outcome/timing only presented in a single study | Low strength of evidence of no benefit for children [underlined: <3] years | Unclear whether findings apply to subgroups defined by parent risk factors; one intervention may not be readily generalizable to other (pediatric practice) settings
KQ 1: Bayley Scales of Development | Caregivers and families | 4; 1,638 caregivers and families | 1 of 4 trials reported higher scores in the intervention arm (mean difference between arms: 3.2; 95% CI, 1.2 to 5.2) | Consistent/imprecise | No evidence of reporting bias | Fair | Outcomes measured at different ages | Low for no benefit | All studies focused on at-risk caregivers and families
KQ 1: Other measures of development | Pregnant mothers | 3; 3,204 | 1 of 3 trials reported statistically significant differences on other development outcomes, but for subset of reported outcome measures and timing | Consistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity in outcome measures | Low for no benefit | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: School performance | School-age children | 1, 1,139 | 1 study found no difference on various school performance measures | Consistency unknown (single trial)/Imprecise | No evidence of reporting bias | Fair | Single trial | Low for no benefit | Single study, applicability to other settings and ages unclear
KQ 1: School attendance | School-age children/families | 1, 1,184 | Self-reported school attendance at age 7: 9/388 (2.35%) vs. 26/405 (6.47%); RR: 0.36, 95% CI, 0.17 to 0.76 No difference in maternal reports of skipping school | Consistency unknown (single trial)/imprecise | No evidence of reporting bias | Fair | Single trial; inconsistent self-report and maternal report | Insufficient | Single study, applicability to other settings and ages unclear
KQ 1: Death | Pregnant or post partum women, 3 studies included only women at risk for maltreatment, all studies includied home visitng | 4; 1,065 | 0 of 4 trials reported statistically significant differences in death | Consistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity in included studies | Low for lack of effect on outcome of death | Unclear whether findings apply to subgroups defined by parent risk factors
KQ 1: Composite maltreatment outcome^ǂǂ^ | Mothers of newborns | 1; 136 mothers | 2/65 (3.1%) vs. 9/71 (12.7%); RR: 0.24, 95% CI, 0.05 to 1.08 Adjusted RR,=0.22 (95% CI, 0.02 to 0.98, p=0.04) | Consistency unknown (single trial)/imprecise | No evidence of reporting bias | Fair | Single small trial | Insufficient | Unclear whether findings apply to subgroups other than teenage first-time mothers
KQ 2: Harms | NA | 0; 0 | No eligible studies | NA | NA | NA | NA | Insufficient | NA

* Long-term CPS reports: adjusted OR, 0.48, 95% CI, 0.23 to 1.0, in one study (3 year-followup, 157 participants); AOR:1.13, p>0.1 in second study (5-year-followup, 1,173 participants); p=0.04 in another study (13-year followup, 216 participants, no effect size provided).

† Calculations based on N randomized.

ǂ Defined as hitting with the hand or objects, biting, burning with objects or by immersion, twisting, shaking, throwing or pushing so as to cause a fall, or hair pulling; identified from review of public agency documents from the Tennessee Department of Human Services.

§ Defined as abandonment, leaving a child with an inappropriate caretaker, gross failure to seek medical care, failure to provide shelter or nutrition, or gross failure to provide for normal intellectual development; identified from review of public agency documents from the Tennessee Department of Human Services.

ǁ Outcomes with no statistically significant results include mean number of ED visits for accidents and injuries (1 study), proportion of children with ED visits for injuries and ingestions (1 study), number of children using the ED (2 studies), and total ED visits (1 study).

¶ Outcomes with no statistically significant results include number of hospitalizations due to nonaccidental injury to the neonate (1 study), number of children hospitalized because of child abuse and neglect (1 study), proportion of children hospitalized for injuries and ingestions (1 study), number of children hospitalized for ambulatory-care sensitive conditions (1 study), number of children rehospitalized (1 study), mean number of all-cause hospitalizations (3 studies), and total count of hospital stays (1 study).

# One study reported statistically significant differences on each of the following: mean and proportion of children with higher externalizing behaviors at 12 months; internalizing behaviors at 2 years and 3 years; behavior problems at 5, 6, and 9 years; and more maternal concerns on the child behavior checklist.

** Outcomes with no statistically significant results include internalizing behaviors at 6 and 12 months (1 study); child behavior at 2 years (1 study), 30 to 33 months and 5.5 years (1 study), and 7 years (1 study); and internalizing and externalizing behaviors at 9 years (1 study).

†† Outcomes included dysregulation, sleep problems, social skills, attention and social problems, school-related conduct outcomes, and infant social and emotional adjustment.

ǂǂ Defined as infant death, severe nonaccidental injury, and involuntary foster care placement.

Abbreviations: AOR=adjusted odds ratio; CI=confidence interval; CPS=child protective services; EPC=Evidence-based Practice Center; ED=emergency department; KQ=key question; NA=not applicable; OR=odds ratio; RR=relative risk; vs.=versus.

Our evidence consisted entirely of RCTs and almost entirely of interventions that included home visits. Trials generally focused on young mothers and drew from vulnerable populations. Some interventions, such as the Nurse Family Partnership and Healthy Families, were tested in multiple settings. Nevertheless, the 21 included trials differed substantially in other respects, such as the populations of interest, baseline risk of maltreatment, intervention intensity and duration, and outcomes measured. These underlying characteristics may explain variations in the effectiveness of the intervention, but the evidence base for each outcome was not extensive enough to identify any patterns.

### Harms of Interventions (Key Question 2)

We did not find any trials reporting harms of interventions to prevent child maltreatment. We had prespecified harms to include stigma, labeling, legal risks, risk of further harm to the child, and dissolution of the family, but we also intended to include other harms as reported. We did not find any trials or observational studies on harms of these interventions.

## Limitations of the Review

As with the previous review for the USPSTF, we restricted inclusion to studies focused on preventive interventions for children who had not yet experienced maltreatment. Therefore, we are unable to determine whether child maltreatment prevention interventions are effective for children who have experienced maltreatment.

Limitations of the evidence relate primarily to the considerable diversity of the interventions and the uncertainties stemming from such heterogeneity. Although nearly all included trials had a home visiting component, several aspects of this particular activity differed. These included the nature and theoretical basis of the interventions delivered during the home visits, credentials of the home visiting staff, and intensity and duration of the intervention.

In addition, all trials involved implementing multiple components. Complex, multicomponent interventions need to report the theoretical foundation for the intervention to help interpret the results and reproduce successful interventions.^122^ Study authors generally did not provide a theory of change or logic model that identified components essential to the success of the intervention. Without theoretical or contextual information on critical intervention components, we cannot determine how successful interventions are different from unsuccessful interventions. This lack of information limits our ability to understand when and how interventions work.

Additionally, the question of applicability of the findings to other pediatric or caregiver populations (e.g., with lower or higher risk profiles) and other settings (e.g., with fewer resources) remains uncertain.

Studies focusing on short-term outcomes of relatively rare events such as hospitalizations, removal from the home, and reports to CPS generally did not find statistically significant results. The few trials that did assess measures over the long term reported mixed results. The extent to which positive results in long-term trials can be attributed to the interventions themselves, to contextual factors such as the resources and abilities of the investigators and sponsoring institutions, or to intervening factors is unclear.

Notably, we found no evidence on harms of child maltreatment interventions. We also did not find any evidence on risky behaviors or outcomes, self-injurious behaviors, or suicidality. We limited our evaluation to direct or proxy measures of abuse or neglect and their sequelae. We have not evaluated the effectiveness of home visiting and other interventions for their many other potential outcomes (e.g., maternal outcomes, family functioning, long-term functioning of the child).

Finally, we did not examine the effects of changes in national, state, county, or municipal laws or regulations. We also did not evaluate the effect of universal interventions that might be delivered in communities rather than to individuals. Although prevention of child maltreatment can be undertaken through changes in policy and through community interventions, these activities lie outside the purview of the USPSTF.

## Future Research Needs

Significant uncertainties in the evidence on interventions that are feasible in or referable from primary care settings on benefits for maltreatment prevention and the absence of information on harms point to the need for further research on child maltreatment preventive interventions.

Funders of new studies need to consider the benefits of investing in entirely new and unproven interventions versus reproducing interventions with some evidence of effectiveness. The latter option would include evaluating interventions modified to address lessons learned in an initial efficacy study or programs adapted to the needs of somewhat different settings or populations.

Reproducing studies of successful interventions requires that investigators clearly identify which intervention components are critical, which also means describing all parts of the intervention or program in considerable detail. Researchers should also specify the degree of fidelity to those components that is needed or expected and comment on the deviations from fidelity that were necessary in earlier studies and, thus, should be evaluated in further research.

Additionally, efforts to test interventions in new settings will need to address issues of applicability and acceptability. New settings may not have the personnel, resources, or organizational commitment found in the original trials. These settings may need adaptations for specific demographic traits and risk factors in the new community. Acceptability in new settings requires stakeholder buy-in. Effective implementation requires a commitment of resources in the short and long term if evidence-based interventions are to be sustained in a clinical practice setting.

Community-based participatory research, when applied in trial designs, can help address the relevance of an intervention for the community. These approaches, for existing interventions, can also inform how the intervention might be tailored, while still preserving its essential elements. They also enhance rigor, for example, by increasing family engagement and exposure to the intervention and reducing attrition.

Future intervention studies are needed with families where known risk factors for child maltreatment, particularly substance abuse and domestic violence, are present. Interventions with these highly vulnerable and challenging-to-serve populations necessitate multifaceted and innovative interventions. These should be integrated into the existing community-based service infrastructure, be trauma informed and culturally sensitive,^123^ and address known protective factors that reduce the likelihood of maltreatment (e.g., reducing social isolation, strengthening household financial security, family planning/birth spacing).^3,^ ^124^

Interventions that attempt to address root causes of family violence will have to address multiple risk factors and may require structural changes in the community to provide greater family support. Such complex interventions should be evaluated on a broad set of outcomes that include child-, parent-, and family-level outcomes. However, studies that evaluate long-term and broadly defined outcomes have a greater opportunity for bias and confounding by secular factors and trends that may not be measured concurrently. For that reason, new studies will need to carefully measure and control for co-interventions and contamination over the long term.

Studies should also account for the family’s engagement (or lack thereof) in community-based services. Such programs may be able to bolster short-term gains from participation in a time-limited intervention and sustain a positive trajectory for the family.

To address the intervention needs of high-risk families, researchers should consider adapting successful interventions from relevant studies that examine prevention of maltreatment recurrence. Future studies could adapt such successful interventions, particularly for children known to be in a high-risk pool (e.g., children referred to the child welfare system without substantiated maltreatment).

Although clinicians may perceive a need for better risk assessment instruments, studies thus far have not demonstrated high sensitivity or specificity for such tools. Poor accuracy of instruments, when coupled with the potential harms of screening—particularly removal of the child from the home, stigma, and erosion of trust and communication between the health care provider and the family—raises concerns about any prevention approach that is based on screening for risk.

Investigators of new studies will need to consider the intensity of planned interventions. Intensity can reflect numerous program characteristics: overall length of the program; number, duration, and nature of interactions (e.g., face-to-face, telephone); and training of intervention staff. New studies that implement low-intensity interventions should clarify how such interventions are anticipated to have long-term effects on caregiver behavior. New studies implementing high-intensity interventions will additionally need to account for the potential effects of a long-term therapeutic relationship between the primary care provider and family that is independent of the intervention.

Given the current state of home visiting programs and the benefits in other outcome areas, we acknowledge the challenges of new studies to determine effectiveness of various approaches (such as the need for larger sample size, higher fidelity and theoretical basis, and possibly more intense services).

Recruitment of participants in these trials can be challenging. Some direct and proxy measures of child abuse and neglect are rare. A combination of small sample sizes and rare outcomes contribute to lack of precision in results. Greater support of pragmatic designs can increase the evidence base. A variety of policy and analytic techniques that allow for rigorous evaluation using quasi-experimental designs and a broader set of data collection and analytic techniques can be used to strengthen inference about causality. Funders of child maltreatment prevention efforts and other home visiting interventions should consider common measures of intervention fidelity; common outcome assessments; and data sharing recommendations, incentives, or requirements. Further, funders should consider supporting robust analyses that take advantage of implementation and evaluation of programs at the individual and jurisdictional levels.

## Ongoing and Unpublished Studies

We identified three ongoing trials that are potentially relevant to this topic. One is a Canadian trial^125,^ ^126^ of the Nurse-Family Partnership model; two trials testing this model in Elmira, New York,^98–102^ and Memphis, Tennessee,^96,^ ^97^ have been included in this review. A second trial is enrolling families of children with special health care needs and provides a behavioral intervention intended to improve parenting skills and prevent child neglect.^127^ Finally, a third trial aims to enhance coping and resilience by improving the quality of the parent-child relationship.^126^ It includes families with young children through 36 months at risk for maltreatment. No eligible outcomes were reported in preliminary results.^128^

## Conclusions

On the whole, the evidence base on interventions feasible in or referable from primary care settings to prevent child maltreatment does not consistently demonstrate benefit. No information was available about possible harms of these interventions. Additional research on interventions that address a comprehensive array of risk factors and evaluate outcomes over the long term may help identify effective, generalizable, and acceptable interventions.