# Chapter 3 Results

## Literature Search

We identified 2,266 unique records and assessed 280 full texts for eligibility (Figure 2). We excluded 247 records for various reasons detailed in Appendix C and included 22 RCTs of good or fair quality (in 33 articles). All included trials addressed KQ 1; none addressed KQ 2. Of the 22 included trials, 12 (in 21 articles [16 previously included, 5 newly identified]) had been included in the 2013 report for the USPSTF, and 10 (in 12 articles) are newly identified.

Figure 2 Summary of Evidence Search and Selection

*Thirteen RCTs (in 16 publications) were excluded for poor quality and used in sensitivity analyses for KQ 1.

Abbreviations: KQ=key question; RCTs=randomized, controlled trials; USPSTF=US Preventive Services Task Force.

Figure 2 is the preferred reporting of systematic review and meta-analysis (PRISMA) tree. There were 44 studies identified from prior USPSTF reviews, 2090 new references identified through database searching, and 177 additional citations identified through reference lists and other sources. After duplicates were removed, the title and abstracts of 2266 references were screened for potential inclusion. Of these, 1986 were excluded and 280 were deemed appropriate for full-text review to assess their eligibility. After full-text review, 247 records were excluded: 20 for ineligible publication type, 45 for ineligible population, 27 for ineligible intervention, 8 for ineligible comparison, 79 for ineligible outcome, 16 for ineligible setting, 15 for ineligible study design, 4 for ineligible country or region and 1 that was not in English, 4 were systematic reviews used to identify relevant studies, 9 were ongoing studies with no publication, 3 were irretrievable, and 16 were excluded for poor overall study quality. Ultimately, 33 publications representing 22 randomized controlled trials were not excluded for the aforementioned reasons and are included in this review. All of these are used in the analysis for KQ1, while none provided information for KQ2. The 16 publications excluded for poor quality represent 13 randomized controlled trials and are used in sensitivity analyses for KQ1.

Details of quality assessments of included studies and studies excluded based on poor quality are provided in Appendix E. Appendix B1 lists the eligibility status of studies included in the previous review. Appendix D presents details for included studies in Evidence Tables. Appendix F presents sensitivity analyses to account for poor-quality studies that were excluded from the review.

### Overview of Study Characteristics

Table 2 summarizes study characteristics for all trials used to answer KQ 1. Additionally, Appendix F provides detailed characteristics of the evidence base for each outcome. The evidence base spans more than three decades; the earliest included study recruited participants in 1976^89^ and the most recent through 2010.^90^ Nearly all trials (21/22) had a home visiting component; some trials present results from attempting a similar model of home visiting interventions in different settings (e.g., the Healthy Families intervention in Alaska^91,^ ^92^ and New York;^93,^ ^94^ replications^90,^ ^95^ of the Nurse Family Partnership,^96–102^). More than two-thirds of the trials recruited women who were age 20 years or older, on average. The majority of trials included a usual care comparator (19/22 trials) and were set in the United States (16/22). In other respects, however, the evidence base is heterogenous in study populations and interventions.

Table 2 Characteristics of Interventions to Prevent Child Maltreatment

Study Characteristics^*^ | Subcharacteristics | Number of Studies | Percent
Study quality | Good-quality studies | 4 | 12%
| Fair-quality studies | 18 | 50%
| Poor-quality studies | 13 | 38%
Population characteristics: Enrollment | Enrolled in prenatal period or immediately after birth | 13 | 59%
| Mixed enrolment | 1 | 5%
| Enrolled after the perinatal period | 8 | 36%
Population characteristics: Maltreatment reported at baseline | Reported maltreatment at baseline | 6 | 27%
| Did not report maltreatment at baseline | 16 | 73%
Population characteristics: Risk status | Parent identified to be at risk | 12 | 55%
| Child identified to be at risk because of birth status (premature or low birthweight) | 2 | 9%
| Participants not specifically identified to be at risk | 7 | 32%
Population characteristics: Age of mother | Most or all mothers under age 20 years | 7 | 32%
| Mothers age 20 years or older on average | 15 | 68%
Intervention characteristics: Home visits | Home visit component | 21 | 95%
| No home visit component | 1 | 5%
Intervention characteristics: Personnel | Clinical personnel involved in care | 15 | 68%
| No clinical personnel | 7 | 32%
Comparator | Usual care comparator | 19 | 86%
| No usual care comparator | 3 | 14%
Geographic setting | United States of America | 16 | 73%
| United Kingdom | 3 | 14%
| Canada | 1 | 5%
| Australia | 1 | 5%
| New Zealand | 1 | 5%

* For all characteristics other than study quality, the table presents data from good- or fair-quality studies only.

† We limited inclusion to studies reporting less than 50 percent of cases experiencing maltreatment at baseline.

Regarding enrolled populations, 13 trials enrolled mothers or mothers prenatally or immediately after birth; the mean age of infants in the 9 other trials ranged from less than 6 months to 8 years. One study enrolled fathers. Fewer than one-third of the trials reported maltreatment at baseline; other trials either did not specify or enrolled women during pregnancy.

More than one-half identified participants or infants to be at risk. Risk factors included health status of the infant, demographic and socioeconomic characteristics of the mother or family, and prior substance abuse.

Regarding treatment, as noted above, 21 of 22 included trials featured home visits. The exception was one trial focusing on behavioral therapy for male patients entering outpatient alcohol treatment who had legal guardianship of at least one child between ages 8 and 12 years.^103^ For the trials with home visit components, the content, use of other components, personnel, intensity, and duration varied. Although the specific purpose of the home visiting program varied by trial, trials described the following activities: assessing family needs; developing a relationship between the home visitor and the client; providing information, referral, and parent education; promoting child health, safety, and development; providing clinical care; enhancing family functioning and positive child-parent interactions; building supportive networks; and creating family plans to support parental life course development and self-sufficiency. A minority of trials featured home visit services as the sole intervention.^91–94,^ ^104–111^ Thirteen provided home visits in the context of clinical support.^89,^ ^90,^ ^95–98,^ ^112–120^

Fifteen trials involved clinical personnel in some capacity, which included nurses or mental health professionals sometimes serving as home visitors or providing comprehensive pediatric service as an intervention component. Of the 21 home visit trials, seven had nurses as home visitors,^90,^ ^95–98,^ ^108,^ ^109,^ ^113,^ ^119^ two had mental health clinicians as home visitors,^110,^ ^117^ four had paraprofessional home visitors,^89,^ ^93,^ ^107,^ ^112^ and one had peer home visitors.^118^ The remaining trials did not specify the training of the home visitors.^91,^ ^92,^ ^104–106,^ ^111,^ ^114–116,^ ^120^ The duration of the intervention ranged from 3 months^89,^ ^103^ to 3 years.^108,^ ^109,^ ^115,^ ^116^ The planned number of sessions, when reported, ranged from 5^119^ to 41 sessions.^104,^ ^105^

### Key Question 1 Benefits of Interventions to Prevent Child Maltreatment on Direct or Proxy Measures of Maltreatment

#### Reports to Child Protective Services

Thirteen trials (14 publications) reported on reports to CPS, and one trial (one publication) reported on safeguarding actions (Appendix D, Tables 11, 13 present data on 13 trials).^89–91,^ ^93,^ ^95,^ ^98,^ ^103,^ ^104,^ ^107–109,^ ^111,^ ^113,^ ^114,^ ^117^ All eligible trials reported their first results during the intervention (1 year from baseline), at the end of the intervention, or within a year of the completion of the intervention. A subset of trials reported outcomes at one or more time points after the first analysis of results. The timing of these reports varied, from within 6 months of the initial results,^114^ 1^93,^ ^117^ to 2 years after the initial results,^117^ or over the longer term (6 years after the initial results,^93^ when the child was 7 years of age,^94^ or 13 years after the initial results, when the child was 15).^100–102^

##### Results for First Followup

The pooled odds ratio (OR) from 10 trials, all having reported results within a year of completion, suggested no difference between arms (OR, 0.94; 95% confidence interval [CI], 0.72 to 1.23, I^2^: 6.3%; 11.1% [135/1211] vs. 11.8 [144/1223] Figure 3). Four trials could not contribute to the meta-analysis. One trial reported only relative risks (RR; i.e., no raw data) with asymmetric confidence intervals that we could not recalculate.^104^ A second provided counts without standard deviations or frequencies (no statistically significant differences; results not reported [not included in Appendix tables]).^89^ A third trial did not specify the time period of outcome measurement, reporting only that the arms did not differ significantly, with a reported p=0.769.^107^ A fourth trial reported safeguarding in the United Kingdom. We did not include this outcome in the meta-analysis because it included actions beyond reports to child protection. The outcome came from any record in general practitioner notes indicating the initiation, progression, or closure of a safeguarding process.^90^ These records included initial assessment, being identified as a child in need, and child protection conferences. The study found higher rates of safeguarding in the intervention arm (adjusted OR [AOR], 1.85; 95% CI, 1.02 to 2.85).^90^

Figure 3 Child Protective Services Reports: Pooled Results

For studies with multiple arms, the pooled estimates averages the treatment effect from active arms and is presented as a “combined arm.” Finello et al present results from a combination of home health and home visits, home health alone, and home visits alone. Because the trial reports cases only for the home health arm, the pooled analysis includes the home health arm only. Lowell et al did not report number of events per arm, the total N analyzed for both arms is 117.

Abbreviation: CI=confidence interval.

Figure 3 displays a forest plot of the odds ratios for having any Child Protective Services reports after participating in a child maltreatment preventive intervention from 10 trials. Meta-analysis of all 10 trials resulted in an odds ratio of 0.937 with a 95 percent confidence interval of 0.715 to 1.227; 135 of 1211 in the intervention arms and 144 of 1223 in the control arms had Child Protective Services reports. The I-squared for this analysis was 6.3 percent.

##### Results for Subsequent Followup

Trials reporting additional results within 6 months^114^ or 1 year^93,^ ^117^ of the original results also reported no difference between the arms.

Trials measuring outcomes for later time points provided mixed results: two trials reported statistically significant differences and one reported no difference. One trial measured outcomes at 36 months from baseline and reported a statistically significant difference favoring the intervention arm; the trial reported a higher probability of no involvement with CPS in the intervention arm (AOR, 2.1; 95% CI, 1.0 to 4.4).^117^ A second trial reported outcomes at 7 years (5 years after the end of intervention^93,^ ^94^) and reported no differences between arms in the cumulative rate of the biological mother or the target child being confirmed as a subject or a victim in CPS reports through 7 years of age (27.1% vs. 29.6%; AOR, 1.13, p>0.1; CIs not reported [161/594 vs. 171/579; calculated OR, 1.13; 95% CI, 0.87 to 1.45]).^94^ A third trial followed children through age 15 but did not provide sufficient details for independent calculation of effects. The authors noted that the intervention group had fewer child maltreatment reports involving the mother as perpetrator (p=0.01),^101^ fewer child maltreatment reports involving the study child (p=0.04),^101^ and fewer verified reports of parents as perpetrators of child abuse and neglect (p<0.001).^100^ This trial also evaluated time to event and found that the treatment effect by time period was significant with longer periods of survival free of CPS reports for children ages 4 to 15 years than for children from birth to age 4 years.^102^

#### Removal of Child From Home

Five trials^104,^ ^105,^ ^112,^ ^113,^ ^118,^ ^119^ reported on outcomes relating to removal of the child from the home. Four trials contributed to a pooled analysis of removal of the child from the home across time points ranging from 12 months to 3 years after baseline (Appendix D, Table 14).^104,^ ^105,^ ^112,^ ^113,^ ^119^ The results show no statistically significant differences between study arms on this outcome (3.5% [11/313] vs. 3.7% [11/296]; OR, 1.09; 95% CI, 0.16 to 7.28; I^2^, 61.8%; 4 trials; N: 609; Figure 4).

Figure 4 Removal of the Child From the Home: Pooled Results

Abbreviation: CI=confidence interval.

Figure 4 displays a forest plot of the odds ratios for a child being removed from the home after participating in a child maltreatment preventive intervention from 4 trials. Meta-analysis of all 4 trials resulted in an odds ratio of 1.089 with a 95 percent confidence interval of 0.163 to 7.282; 11 of 313 in the intervention arms and 11 of 296 in the control arms experienced child removal. The I-squared for this analysis was 61.8 percent.

One trial, reporting on removals at birth, included CPS-involved placements and informal care arrangements (type of placement by study group not specified).^118^ The trial also collected data on the percentage of children in out-of-home care at followup but did not differentiate new removals from placements at the time of birth. Because of measurement issues with the followup outcome, we focused on removal rates only at birth and did not include results in the pooled analysis above. This trial reported results with a different direction of effect but no statistically significant difference between study arms; 9 percent of the intervention group and 4 percent of the control group had been placed in out-of-home care at birth (the intervention began during pregnancy) (N=187/225; RR, 2.33; 95% CI, 0.66 to 8.20).

#### Other Measures of Abuse or Neglect

Two RCTs^106,^ ^112^ reported on study-specific measures of abuse (Appendix D, Tables 16, 17). These measures included physical abuse (hitting with the hand or objects, biting, burning with objects or by immersion, twisting, shaking, throwing or pushing so as to cause a fall, or hair pulling; identified from review of public agency documents from the Tennessee Department of Human Services)^112^ and neglect (abandonment, leaving a child with an inappropriate caretaker, gross failure to seek medical care, failure to provide shelter or nutrition, or gross failure to provide for normal intellectual development; identified from review of public agency documents from the Tennessee Department of Human Services,^112^ and results from the Framingham Safety Survey about household hazards^106^). One trial reported no differences, finding 13/141 cases (9.2%) of physical abuse in the intervention arm vs. 8/122 (6.6%) in the comparator arm (RR, 1.4 [95% CI, 0.58 to 3.62]). The same study^112^ reported 15/141 cases (10.6%) cases of neglect in the intervention arm vs. 5/122 (4.1%) in the comparator arm (RR, 2.79 [95% CI, 0.98 to 7.91]).^112^ The second reported a statistically significant difference, but the clinical importance of the effect is unclear. The trial reported mean values on the Framingham Safety score of 1.72 (intervention) vs. 1.68 (comparator); higher scores represent greater safety. The trial noted a p-value of 0.03 for this outcome but provided no measures of dispersion for us to calculate mean differences independently.^106^

#### Injuries With a High Specificity for Abuse or Neglect

One trial found no statistically significant differences in the rates of nonaccidental injuries (0/64 vs. 1/71; calculated RR, 0.37; 95% CI, 0.015 to 8.91) (Appendix D, Table 18).^119^

#### Emergency Department Visits

Eleven trials reported on emergency department (ED) visits (Appendix D, Tables 20, 22).^89–92,^ ^96–102,^ ^104,^ ^105,^ ^108–110,^ ^113–116,^ ^120,^ ^121^ The timing and type of outcome measurement varied substantially across trials; several trials presented outcomes at multiple time periods. To ensure that we captured all the evidence without inappropriately combining different periods of followup, we present the results by timing of outcome measurement first and then by type of outcome measurement for each time period. The results were generally inconsistent in direction of effect.

##### Results for Followup <1 Year

Two trials reported outcomes at 6 months of corrected gestational age and found no statistically significant difference in the percentage of infants in each of four arms who used the ED from age 0 to 6 months (p=0.637) in one study^114^ and AOR: 1.52; 95% CI, 0.86 to 2.70 in the second study.^90^

##### Results for Followup From 1 to <2 Years

Of these 10 trials, six reported ED visit outcomes at between 1 and 2 years after enrollment or recruitment.^89,^ ^98–102,^ ^104,^ ^105,^ ^110,^ ^114,^ ^120,^ ^121^ Measurement of outcomes varied and included (1) mean number of all-cause ED visits, (2) mean number of ED visits for accidents and injuries, (3) number of children using the ED for any reason, and (4) total ED visits. Overall, the results are inconsistent in demonstrating benefit.

Because three of five trials reporting on mean number of all-cause ED visits do not provide measures of dispersion, the results cannot be pooled.^98,^ ^105,^ ^110^ Three trials reported no statistically significant differences.^105,^ ^110,^ ^120,^ ^121^ Two trials reported statistically significant differences at or near the p=0.05 level.^98,^ ^114^

One trial, which reported the mean number of ED visits at 12 months specifically for accidents and injuries, showed no statistically significant difference between study arms.^98–102^

Two trials reported the number of children in each group who used the ED for any reason; calculated RRs indicate no differences for intervention arms compared with usual care at either 12 months or 18 months.^114,^ ^120,^ ^121^

One trial of extended contact between mothers and neonates with or without home visits, when compared with usual care, reported on total number of ED visits per arm (rather than means; no standard deviations were reported). The study authors noted a lack of statistical significance.^89^

##### Results for Followup From 2 to <4 Years

Of these 11 trials, six reported ED visit outcomes at 2 to <4 years of followup.^90–92,^ ^96–102,^ ^108,^ ^109,^ ^115,^ ^116^ Variations in the type of outcome reported again precluded pooling. Outcomes included (1) mean number of all-cause ED visits; (2) mean number of ED visits for accidents, injuries, and ingestions; (3) number of children seen in the ED; (4) number of children seen for accidents or injuries; and (5) number of children seen for injuries or ingestions. Overall, the results are inconsistent in demonstrating benefit.

Two trials reported the mean number of all-cause ED visits over the 2-year study period.^91,^ ^98^ One trial reported a statistically significant difference;^98^ the second reported no statistically significant differences.^91^

Two trials reported the mean number of ED visits specifically for accidents, injuries, or ingestions.^96–102^ One reported no difference;^96^ the other reported a statistically significant reduction in mean number of ED visits for the nurse-visited arm compared with the control arm (p=0.03).^98^

Two trials^91,^ ^92,^ ^115^ reported the number of children seen in the ED but found no statistically significant difference between study arms (AOR, 1.23; 95% CI, 0.74 to 2.05;^91,^ ^92^ AOR, 1.21 95% CI, 0.96 to 1.52^115^).

Two trials reported the number of children seen specifically for accidents or injuries.^108,^ ^109,^ ^115,^ ^116^ One study found a statistically significant difference (OR, 0.59; 95% CI, 0.36 to 0.98),^108,^ ^109^ and the other found no statistically significant difference (AOR, 0.94; 95% CI, 0.65 to 1.34).^115,^ ^116^

One trial found no statistically significant difference in the proportion of children seen specifically for injuries and ingestions (AOR, 1.16; 95% CI, 0.92 to 1.46).^90^ This study also combined emergency department visits and hospitalizations and did not find any statistically significant differences (AOR, 1.32; 97.5% CI, 0.99 to 1.76).

##### Long-Term Followup (≥4 Years)

Two trials reported long-term outcomes at 4^99^ and 5 to 5.5 years;^116^ they yielded mixed results. One trial, which evaluated outcomes at 4 years for three groups,^99^ reported a 35 percent reduction in ED visits of all types for children in the nurse-visited group (p=0.0008) compared with rates for the control group but no difference in the number of ED visits for injuries or ingestions (p>0.05); the trial did not report raw numbers, RRs, or CIs. One trial, which reported the proportion of children who had used the ED in the past year at the 5- to 5.5-year followup,^116^ showed no statistically significant difference between groups (10% vs. 9.2%; AOR, 0.96; 95% CI, 0.73 to 1.27).

#### Hospitalization

Twelve trials reported on hospitalization outcomes (Appendix D, Tables 24, 26).^89–92,^ ^96,^ ^99,^ ^104,^ ^108,^ ^109,^ ^113,^ ^114,^ ^116,^ ^119,^ ^121^ Because of substantial heterogeneity in outcome definitions and time periods of interest, results could not be pooled.

Outcomes varied in their degree of specificity to child abuse and neglect. They included (1) number of children with hospital admission as a result of an injury that was referred for independent investigation by the Family and Children’s Services staff and was concluded to have arisen as a result of a nonaccidental injury to the neonate,^119^ (2) number of children hospitalized because of child abuse and neglect,^108^ (3) proportion of children hospitalized because of injury or ingestion;^90^ (4) number of children hospitalized for ambulatory-care sensitive conditions, (5) number of children rehospitalized, (6) number of children with all-cause hospitalization, (7) mean number of all-cause hospitalizations, (8) total counts of hospital visits, (9) mean number of hospital days, and (10) types of injuries reported among those hospitalized. In general, the evidence does not demonstrate benefit for the active intervention arm(s).

One trial of a postnatal home visitation program led by nurse-midwives found no differences in hospital admissions at 18 months resulting from injury referred for independent investigation by the Family and Children’s Services staff and concluded to have arisen as a result of a nonaccidental injury to the neonate.^119^

One trial each found no difference in the number of children hospitalized because of child abuse and neglect,^108^ the number of children hospitalized for ambulatory-care sensitive conditions,^91^ and the number of children rehospitalized at 14 days and 18 months (the original cause was not specified).^113^

One trial found no statistically significant differences in the proportion of children hospitalized because of injury or ingestion at 6 or 24 months.^90^ As noted above, the study did not report any significant differences after pooling emergency department visits and hospitalizations.

Four of five trials reporting on the number of children hospitalized found no differences.^92,^ ^104,^ ^105,^ ^116,^ ^120^ One trial reported four outcomes for the number of children hospitalized (6 months followup, 12 months followup, less than 24 hours stay, more than 24 hours stay); the investigators reported no statistically significant differences for three of these outcomes. The exception was the number of children hospitalized for more than 24 hours at 6 months (lower numbers in the intervention arm when compared with the control arm, p=0.017).^114^

One trial found that the home visitation group had lower overall rates of hospital admission for unintentional injury than the control group at the 9-year followup (28.3% vs. 42.1%, p<0.05).^108,^ ^109^

Three trials found no statistically significant differences in the mean number of all-cause hospitalization.^96,^ ^99,^ ^120^ One trial reported no differences in total counts of hospital visits (measures of dispersion not reported).^89^

With respect to other hospitalization outcomes, one trial found significantly fewer mean hospital days for nurse-visited children in a home health program than for children in the usual care arm (log incidence difference=−0.66; 95% CI, −1.21 to −0.13; p<0.05).^99^ Other home visitation trials did not find between-group differences in hospital days.^104,^ ^120^

One trial also reported differences in the severity of injuries between home visitation program groups.^96^ The three nurse-visited children from this trial who were hospitalized had burns to the face, coin ingestion, and ingestion of iron medication; the 13 children in the control group were hospitalized for fractures (fibula, tibia, skull [two children]), head trauma without skull fracture [three children]), strangulated hernia with delay in care, coin ingestion, suspected child abuse and neglect, burns (face and neck, both legs), and finger injury with osteomyelitis.^96^

#### Failure to Thrive

One trial reported on failure to thrive. It found no statistically significant differences between study arms for this outcome (0% [0/39] vs. 2.5% [1/40]; RR, 0.34, 95% CI, 0.01 to 8.14) (Appendix D, Table 28).^113^

#### Failure to Immunize

One trial reported on failure to immunize. It found no statistically significant differences between study arms in the rate of no vaccinations at 6 months (calculated RR, 0.49; 95% CI, 0.16 to 1.52) (Appendix D, Table 30).^119^

### Key Question 1 Benefits of Interventions to Prevent Child Maltreatment on Other Outcomes

#### Internalizing and Externalizing Behavior

Six trials reported on internalizing (depression, anxiety) and externalizing (disruptive, aggressive, or delinquent) behavioral outcomes in children (Appendix D, Tables 32, 34).^91–94,^ ^96,^ ^97,^ ^108,^ ^109,^ ^115–117^ As with other outcomes, the evidence included substantial heterogeneity in the timing and type of outcome measurement. Overall, the findings are inconsistent. Overall, three of six trials found a reduction in behavior difficulties in children in primary care interventions to prevent child maltreatment.^91,^ ^92,^ ^108,^ ^109,^ ^117^

##### Results for Followup ≤2 Years

One trial^117^ reported behavior outcomes at 6 months and 12 months^117^ on the Internalizing and Externalizing scales of the Infant Toddler Social Emotional Adjustment Scale (ITSEA). The study presented results that adjusted for baseline values and repeated measures and found a significant effect of the intervention on the proportion of children with ITSEA externalizing behaviors (p<0.05) and mean ITSEA externalizing behaviors at 12 months (mean score: 13.8 vs.18.4, effect size 0.094) but not at 6 months. The study found no statistically significant differences between arms for proportion of children with ITSEA internalizing behaviors or mean ITSEA internalizing behavior scores at 6 months or at 12 months.

##### Results for Followup for 2 to <4 Years

Five trials reported outcomes between 2 and 4 years of followup; three found no differences and two found statistically significant differences. One trial^96,^ ^97^ of nurse home visits examining child behavior outcomes at 2 years of age using the Child Behavior Checklist (CBCL) found no difference between arms at age 2 years. A second trial examined outcomes of a paraprofessional home visitation program at age 7 years on five subscales of the CBCL measuring rule-breaking, aggressive behaviors, social problems, anxious depressed, and withdrawn depressed behaviors but found no significant differences between arms.^93,^ ^94^ One trial reported outcomes at 30 to 33 months^115,^ ^116^ and found that no statistically significant differences between intervention and control arms for the proportion or mean scores of children with aggressive behavior problems or anxious or depressed problems based on CBCL scores (although trends favored the control arm).

One trial^91,^ ^92^ found that children in the intervention group were more likely to have a higher percentage of participants with a normal CBCL internalizing score at age 2 years (87% vs. 79%; AOR, 2.06; 95% CI, 1.31 to 3.25) and they had significantly lower mean scores of internalizing behavior problems on the CBCL than usual care (48.2 vs. 51.0, mean difference: −2.8; 95% CI, −4.2 to −1.5). More participants in the intervention group were found to have CBCL externalizing scores in the normal range (82% vs. 77%; AOR, 1.48; 95% CI, 1.14 to 1.94) but no statistically significant differences were found for externalizing behavior problems on the mean CBCL score.

One trial examined outcomes at 36 months.^108,^ ^109^ At 36 months of age, the study reported lower mean scores and rates of internalizing problems (mean score: 9.86 vs. 10.12; OR, 0.13; 95% CI, 0.03 to 0.23; Cohen’s d, 0.26; 95% CI, 0.06 to 0.47; p<0.01) and lower overall mean scores and rates of behavior problems on the ITSEA (mean score: 9.87 vs. 10.11; OR, 0.12; 95% CI, 0.02 to 0.22; Cohen’s d, 0.24; 95% CI, 0.04 to 0.44) but no differences for mean scores for externalizing behaviors as assessed by the ITSEA.

##### Long-Term Followup (≥4 Years)

Three trials evaluated long-term outcomes. One trial reported fewer issues of concern in the intervention when compared with the control arm and two reported statistically significant effects.

One trial that reported outcomes at 36 months reported outcomes again at ages 5, 6, and 9 years.^108,^ ^109^ Behavioral outcomes were assessed again at ages 5, 6, and 9 years using the Strengths and Difficulties Questionnaire, and at age 9 years, the intervention group demonstrated fewer overall behavior problems (mean score: 9.91 vs. 10.08, Cohen’s d, 0.17; 95% CI, 0.06 to 0.29; p<.05).

One trial reported on child internalizing and externalizing behavior problems outcomes at age 9 years, 7 years after the intervention ended, using the Computerized Diagnostic Interview Schedule for Children and found no statistically significant differences between arms for mother or teacher reports of behavior problems (not included in Appendix tables).^96,^ ^97^

In one trial (with trends favoring the control arm at 30 to 33 months) at 5.5 years,^115,^ ^116^ mothers in the intervention group reported no statistically significant differences in borderline or clinical behavioral concerns on the CBCL (20.2 vs. 16.5%; AOR, 1.26; 95% CI, 0.94 to 1.69).

#### Social, Emotional, and Other Developmental Outcomes Not Otherwise Categorized

Five trials evaluated discrete social, emotional, or other developmental outcomes separately from overall measures of externalizing or internalizing problems (Appendix D, Tables 36, 37).^94,^ ^97,^ ^104,^ ^105,^ ^115–117^ The heterogeneity of outcomes precluded meta-analysis, but all trials reported results that were not statistically significant.

One trial evaluated dysregulation midway through the intervention period and at intervention completion and found no significant difference between study arms at 6 or 12 months post-baseline.^117^

Another trial^115^,^116^ reported sleep problems as an outcome, assessed toward the end of the intervention period when the children were 30 to 33 months of age.^115^ The mean scores were not significantly different between the intervention group and control group. Longer-term outcomes from this same trial examined children’s social skills when the children were 5 to 5.5 years of age, again finding no difference between the intervention and control groups (p=0.40).^116^

In a third trial,^94^ researchers assessed attention and social problems using subscales of the CBCL when children were 7 years of age, at 5 years after the intervention had been completed.^94^ The trial demonstrated no significant differences between the intervention and control groups for either attention or social problems.

A fourth trial found no significant differences between study arms in a few school-related outcomes (conduct, antisocial behavior, academically focused behavior, and peer affiliation) at a followup 7 years after the intervention had been completed, when children were 9 years of age.

One trial assessed but did not report infant or toddler social and emotional adjustment outcomes.^104^ A subsequent cost evaluation alluded to the results not being significant but did not report specific outcome data.^105^

#### Child Development as Measured by the Bayley Development Scales

Four trials^91,^ ^92,^ ^96–102,^ ^104^ reported on child development as measured by the Bayley Scales of Child Development (Appendix D, Tables 38, 39). The results generally indicated no differences between intervention and control groups, with the exception of some results from one trial.^92^

Two trials reported Bayley Scale outcomes at 1 year of age; both reported no statistically significant differences.^98,^ ^104^

Two trials reported on Bayley scale outcomes when children were 2 years of age.^92,^ ^96^ One trial reported no difference in the Bayley mental index at 2 years of age.^96^ The other evaluated the Bayley mental and psychomotor indices at 2 years of age and found a significant difference in the Bayley mental development index with those in the experimental group having a 3.2-point higher mean score (mean score: 88 vs. 84.8 [<85 is the threshold for mild delay]; 95% CI, 1.2 to 5.2).^92^ The mean difference between the two groups was not significant for the psychomotor index.

One of these two trials (above) also reported the proportion of children in each group with an index score greater than 85 (i.e., in the normal range).^92^ The experimental group had higher adjusted odds of being in the normal range on the mental index. For the mental index, 58 percent of the experimental group and 48 percent of the control group were in the normal range, with an AOR of 1.55 (95% CI, 1.01 to 2.37). The unadjusted odds were not statistically significant (calculated OR, 1.50; 95% CI, 0.91 to 2.47 [not in Appendix]). The groups were more similar for the psychomotor index, with 85 percent of the experimental group and 80 percent of the control group in the normal range; the differences were not statistically significant (adjusted OR, 1.36; 95% CI, 0.72 to 2.58).

#### Other Development Outcomes

Three trials reported on other outcome measures (Appendix D, Tables 41, 43).^90,^ ^98,^ ^116^ One trial reported no measures of variance but noted that the overall results for a group of infant development tests was not statistically significant.^98^ Another trial found no statistically significant differences in the proportion of parents with a significant concern regarding the child’s development on the Parents’ Evaluation of Development Status (calculated RR, 0.94; 95% CI, 0.76 to 1.16).^116^ A third trial found no statistically significant differences between study arms in maternal concerns regarding cognitive development at 12 months.^90^ Subsequent measures showed fewer concerns in the intervention arm by 24 months. The same study demonstrated better early language scores (the Early Language Milestone Scale score) at 24 months and fewer language concerns at 12 and 18 months in the intervention arm.

#### School Performance

One trial^96^ found no statistically significant differences between the intervention and control arms for mental development at 24 months (Appendix D, Tables 44, 45). At 9 years of age, the same study found no differences on grade point averages averaged across reading and math. The study also found no differences on math and reading achievement test scores in grades 1 through 3.^97^

#### School Attendance

One trial^94^ reported on school attendance and found that children at age 7 years in the intervention group reported skipping school significantly less often than children in the usual-care group (2.35% [9/388] vs. 6.47% [26/405]; RR, 0.36; 95% CI, 0.17 to 0.76) (Appendix D, Tables 44, 45). The same study reported no statistically significant differences using maternal reports of skipping school.

#### Death

Four trials of fair quality reported on the outcome of child death (Appendix D, Table 46).^96,^ ^97,^ ^104,^ ^113,^ ^119^ Variations in the timing and outcome specifications preclude quantitative synthesis. One trial reported mortality at the 6-month followup,^119^ one at 12 months,^104^ and one at 18 months.^113^ Yet another trial reported child deaths at the 9-year followup.^96,^ ^97^ One trial included deaths attributed to sudden infant death syndrome.^113^ One trial included only those deaths for which a child protection concern was known and an open verdict was reached.^104^ The other two trials included all deaths in the period specified for followup.

No study reported statistically significant differences in the rates of child death between intervention and usual-care groups. Three trials reported a lower but nonsignificant rate of child death among children in their intervention groups.^96,^ ^97,^ ^104,^ ^119^ One trial reported a higher but nonsignificant rate of death among children in the intervention group.^113^ In the longest study (9 years of followup),^96,^ ^97^ 1 death occurred in the intervention group (222 participants) and 10 deaths in the control group (of 498 participants). The OR favoring the intervention group was 0.22 (95% CI, 0.03 to 1.74).^96,^ ^97^ Overall rates of death were low (0 to 3%). These were rare events even among these mostly high-risk children.

#### Composite Outcome

One trial reported on a composite outcome comprising infant death, severe nonaccidental injury, and involuntary foster care placement (Appendix D, Table 48).^119^ The investigators found a lower but not statistically significant risk for this measure outcome in the intervention group (3% [2/65] vs. 12.7% [9/71] in the usual-care group; RR, 0.24; 95% CI, 0.05 to 1.08). When adjusted for baseline covariates, the RR was 0.22, 95% CI, 0.02 to 0.98.^119^

### Key Question 2 Harms of Interventions to Prevent Child Maltreatment

We did not find any trials reporting harms of interventions to prevent child maltreatment.