# Chapter 2 Methods

## Response to Public Comments on the Research Plan

Numerous comments received during development of the research plan for the current update requested clarification on the inclusion and exclusion criteria. In response, we revised the analytic framework to specify the population of interest as “children and adolescents from birth to age 18 years”; also, the inclusion criteria no longer exclude children and adolescents with serious behavioral problems.

We clarified that the evidence review will include family-focused interventions, which may be directed at the caregiver and may not include components directed at the child. The review includes interventions thought to be feasible in primary care settings or referred away from primary care settings to specialist care or other programs and includes interventions conducted in labor and delivery settings in hospitals, home settings, and nonspecialty settings. Revisions in response to comments resulted in the addition of two new outcomes: improved school attendance and performance and reduced risky behaviors and outcomes (e.g., sexually transmitted diseases).

## Key Questions and Analytic Framework

The investigators, U.S. Preventive Services Task Force (USPSTF) members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope, key questions (KQs), and analytic framework (Figure 1) that guided the literature search and review. Two KQs guide this review:

1. Do primary care feasible or referable interventions to prevent child maltreatment reduce exposure to abuse or neglect; improve behavioral, emotional, physical, or mental well-being; or reduce mortality among children and adolescents without obvious signs or symptoms of abuse or neglect?
2. What are the harms of primary care feasible or referable interventions to prevent child maltreatment?

Figure 1 Analytic Framework

*The World Health Organization and International Society for Prevention of Child Abuse and Neglect define child maltreatment as including “all forms of physical and/or emotional ill-treatment, sexual abuse, neglect, or negligent treatment or commercial or other exploitation, resulting in actual or potential harm to the child’s health, survival, development, or dignity in the context of a relationship of responsibility, trust, or power” (1). Maltreatment includes physical abuse, neglect, sexual abuse/exploitation, emotional abuse, parental substance abuse, and abandonment.”^3^

Abbreviations: KQ=key question.

The framework begins on the left with the population of interest: children or adolescents without signs or symptoms of current or past abuse or neglect. To the right is an overarching arrow for the framework representing KQ1. It begins with “Primary care–relevant preventive interventions” of child maltreatment on the left and ends with a box on the far right that represents the final outcomes: “Reduced exposure to abuse or neglect; behavioral, emotional, mental, or physical well-being; and reduced mortality.” From this main arrow is a second arrow descending to an oval with the text “Harms” to illustrate the focus of KQ2. A footnote at the bottom of the figure reads “The World Health Organization and International Society for Prevention of Child Abuse and Neglect define child maltreatment as including ‘all forms of physical and/or emotional ill-treatment, sexual abuse, neglect, or negligent treatment or commercial or other exploitation, resulting in actual or potential harm to the child’s health, survival, development, or dignity in the context of a relationship of responsibility, trust, or power.’ Maltreatment includes physical abuse, neglect, sexual abuse/exploitation, emotional abuse, parental substance abuse, and abandonment.”

### Contextual Questions

We include two contextual questions (CQs) to help inform the report:

1. What is the validity and reliability of risk assessment tools to identify children and adolescents who are at risk of child maltreatment?
2. Do primary care–feasible or referable interventions to prevent child maltreatment reduce parent-reported measures of exposure to abuse or neglect?

These CQs were not a part of our systematic review. They are intended to provide additional background information. Literature addressing these questions is summarized in Appendixes A3 and F3, respectively.

### Search Strategies

We searched MEDLINE® (via PubMed), the Cochrane Library, and EMBASE for English-language articles published from November 1, 2011, through December 18, 2017. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, screening tests, interventions, outcomes, and study designs. Appendix B2 describes the complete search strategies.

To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies meeting our inclusion criteria and added all previously unidentified relevant articles. We reassessed all articles in the 2013 report (Appendix B1). Systematic searches in the 2013 report extended through June 2012.^1,^ ^80^ We also included articles from other systematic reviews in our hand-search yield.

We also conducted targeted searches for unpublished literature by searching ClinicalTrials.gov, Cochrane Clinical Trials Registry, and the World Health Organization International Clinical Trials Registry Platform. We continued surveillance of literature through July 17, 2018.

## Study Selection

We selected studies on the basis of inclusion and exclusion criteria developed for each KQ for identifying populations, interventions, comparators, outcomes, timing, settings, and study designs (PICOTS) (Appendix B3). Appendix C lists studies excluded at the full-stage review stage. We imported all citations identified through searches and other sources into EndNote X7.

Two investigators independently reviewed titles and abstracts. We dually and independently reviewed the full text of abstracts marked for potential inclusion by either reviewer. Two experienced team members then resolved disagreements.

### Population

The focus of the review is on children and adolescents (birth through age 18 years) with no known exposure to maltreatment and no signs or symptoms of current or past maltreatment. We required included studies to have a majority of children (>50%) without known exposure to maltreatment and no signs or symptoms of current or past maltreatment. If information on the proportion with known exposure or with signs or symptoms was unavailable in the report, we sent an inquiry to the author. In cases of nonresponse or lack of clarity in the published reports, we planned to include these studies only in sensitivity analysis.

We excluded studies consisting entirely of symptomatic children and adolescents undergoing diagnostic evaluation for conditions related to abuse or neglect, asymptomatic children with known exposure to child maltreatment, children (regardless of symptomatology) who have maltreatment perpetrated against them by a caregiver at baseline, and perpetrators of maltreatment.

### Interventions

We included studies that evaluated services that were feasible in a primary care setting or could be sent as referrals by a primary care provider. These services may have been implemented by a nonclinician; they may also have included home visiting programs, primary care–based programs, respite care, parent education programs, and family support and family-strengthening programs. We excluded communitywide programs only, such as public awareness campaigns or public service announcements, without specific interventions linked to clinical settings.

### Comparators

We included comparators of usual care, delayed interventions, or active interventions that allow for assessment of the independent contribution of the primary care–feasible or referable preventive intervention (e.g., clinical interventions plus media campaigns vs. media campaigns).

### Outcomes

We required that all studies report direct or proxy measures of abuse or neglect. Direct measures include those reflecting physical, sexual, or emotional abuse perpetrated by a parent or caregiver; physical (e.g., failure to thrive), emotional, dental/medical (e.g., lack of immunizations or well-child visits), or educational neglect; reports to CPS; and removal of the child from the home. Proxy measures include injuries (e.g., broken bones, bruises, burns), visits to the emergency department, and hospitalizations. For studies that reported direct or proxy measures of abuse or neglect (other than self-report), we then evaluated behavioral, emotional, mental, or physical well-being.

### Settings

We included studies that occurred in (1) pediatric, primary care, family medicine, or school-based clinics or (2) other settings where services are offered that could result from an assessment by a primary care clinician in a home setting or behavioral health provider’s office. We required that studies were conducted in countries categorized as “very high” on the Human Development Index.^81^

### Study Designs

We limited KQ 1 to randomized, controlled trials (RCTs) and systematic reviews. For KQ 2, we also searched for eligible cohort trials with a control group and case-control studies.

### Studies in the 2013 USPSTF Review

We applied, dually and independently, the inclusion and exclusion criteria described above to studies included in the 2010 USPSTF review with the exception of three irretrievable government reports and gray literature (document links no longer work). We resolved disagreements by discussion and consensus; if necessary, we sought adjudication.

## Data Abstraction and Quality Rating

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings (PICOTS), and study designs (Appendix D). A second investigator checked all data extractions for completeness and accuracy. Among included studies from the 2013 report, one reviewer checked for errors in previously generated abstraction tables and updated them as needed.

We assessed the quality of studies as good, fair, or poor using predefined criteria (Appendix E). We planned to rate the outcomes for KQ 1 (benefits) and KQ 2 (harms) separately for studies as high risk of bias, low risk of bias, or some risk of bias concerns based on a tool developed by the Cochrane Collaboration for assessing the risk of bias of RCTs.^82^ Two investigators independently evaluated the risk of bias of each study. We then cross walked the risk of bias criteria to USPSTF criteria for overall ratings of good, fair, or poor.^83^ We checked the quality ratings of all eligible studies from 2013 to ensure that studies met our current quality rating criteria.

If we identified eligible systematic reviews, we planned to rate the quality of systematic reviews using ROBIS,^84,^ ^85^ a tool designed to evaluate the risk of bias of systematic reviews. Using this tool, each systematic review is rated as low, unclear or some concerns, or high risk of bias. As with the Cochrane tool, low risk of bias corresponds to good quality, high to poor quality, and unclear represents uncertainty. Appendix B4 describes the quality rating criteria for each tool.

We resolved disagreements by discussion and consensus. We rated studies as poor quality (i.e., high risk of bias) for the following reasons: groups assembled initially were not close to being comparable or were not maintained throughout the study, unreliable or invalid measurement instruments were used or not applied equally among groups (including not masking outcome assessment), and intention-to-treat analysis was lacking.

## Data Synthesis and Analysis

We evaluated the findings for each outcome, first using a qualitative approach that considered the clinical and methodological characteristics of the evidence base. We paid close attention to PICOTS criteria in evaluating heterogeneity and summarize study characteristics for the evidence base for each outcome in Appendix F. With relatively rare outcomes such as reports to CPS, removal from the home, and hospitalizations, a longer time period for observation of outcomes allows for a greater accumulation of events, but it also increases both the likelihood of unmeasured co-interventions that vary differentially between arms and the attenuation of intervention effects overall. Because of the potential heterogeneity of combining longer-term outcomes with studies reporting results at or close to the end of the intervention, we generally limited meta-analyses to the first report of outcomes from studies (generally within a year of study completion).

We then presented results either qualitatively or quantitatively. We generated pooled estimates when at least three similar studies were available, using the Comprehensive Meta Analysis program.^86^ For all meta-analyses, we used random effects models and calculated the chi squared statistic and the I^2^ statistic (the proportion of variation in study estimates due to heterogeneity) to assess statistical heterogeneity in effects between studies.^87,^ ^88^ An I^2^ from 0 to 40 percent might not be important, 30 percent to 60 percent may represent moderate heterogeneity, 50 percent to 90 percent may represent substantial heterogeneity, and 75 percent to 100 percent represents considerable heterogeneity.^82^ The importance of the observed value of I^2^ depends on the magnitude and direction of effects and on the strength of evidence for heterogeneity (e.g., p-value from the chi squared test or a confidence interval for I^2^). However, as precision and the number of participants increase, I^2^ may become inflated toward 100 percent and may not reflect clinically relevant heterogeneity.^80^

We presented results from fair- and good-quality studies for each outcome. We excluded poor-quality studies from the main analysis. Sensitivity analysis in Appendix F provide information from poor-quality studies.

## Expert Review and Public Comment

Content experts, representatives of federal partners, USPSTF members, and AHRQ Medical Officers reviewed a draft report. We revised the report in response to peer review comments. Specifically, we edited and clarified text as needed. We also added data on a recently published trial identified by peer reviewers. The report was then posted for public comment. Based on the comments received, we revised the report for clarity and added information to CQ 2 on a newly identified study.

## USPSTF Involvement

This review was funded by AHRQ. Staff of AHRQ and members of the USPSTF participated in developing the scope of the work and reviewed draft manuscripts, but the authors are solely responsible for the content.