# Chapter 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to inform an update of its 2013 recommendation on primary care interventions to prevent child maltreatment. In 2013, the USPSTF concluded that the evidence^1^ was insufficient to assess the balance of benefits and harms. This report will summarize the evidence for the benefits and harms of interventions to prevent child maltreatment and identify key gaps in the scientific literature.^2^ Evidence on interventions for children with signs and symptoms of maltreatment or known exposure to child maltreatment is outside the scope of this report.

## Condition Background

### Condition Definition

Child abuse and neglect, also referred to as child maltreatment, is recognized as a global problem with lifelong health and mental health consequences. From an overarching public health perspective, the World Health Organization and International Society for Prevention of Child Abuse and Neglect define child maltreatment as “all forms of physical and/or emotional ill-treatment, sexual abuse, neglect or negligent treatment or commercial or other exploitation, resulting in actual or potential harm to the child’s health, survival, development or dignity in the context of a relationship of responsibility, trust, or power.”^3^ In the United States, the Centers for Disease Control and Prevention (CDC) have recommended a set of uniform definitions to support public health surveillance of maltreatment.^4^ The CDC definition differentiates child abuse as “acts of commission” and child neglect as “acts of omission.” Words or actions that are deliberate and cause harm, potential harm, or threat of harm are considered acts of commission (e.g., physical, sexual, and psychological abuse). Failure to provide for a child’s basic physical, emotional, or educational needs or to protect a child from harm or potential harm constitutes an act of omission. These acts involve physical, emotional, medical and dental, and educational neglect; inadequate supervision; and exposure to violent environments. The CDC definition specifies that, in either case, harm to a child might not be the intended consequence.

From the legislative perspective, the Federal Child Abuse Prevention and Treatment Act (CAPTA) stipulates key guidance for child protection in the United States. In the most recent CAPTA reauthorization (2010), child abuse and neglect is defined as “At a minimum, any recent act or set of acts or failure to act on the part of a parent or caretaker, which results in death, serious physical or emotional harm, sexual abuse or exploitation, or an act or failure to act, which presents an imminent risk of serious harm.”^5^

The CAPTA definition provides States with minimum standards to apply in their mandatory child abuse and neglect reporting laws (both civil and criminal). This results in considerable variation across States in the statutory descriptions of what constitutes child maltreatment. This definition landscape is further complicated by the fact that States may amend their laws frequently.

The legislative variation in definitions of maltreatment across and within individual States, along with definitional variation across social service delivery systems and sectors within and outside of the United States, has led to a lack of common operational definitions and measurement in child abuse and neglect research. These measurement challenges, in turn, continue to undermine the accuracy of case identification in research, monitoring, and assessment of the magnitude and nature of child maltreatment and impact of interventions in addressing prevention.^6^

### Prevalence and Burden of Disease

Reports of child maltreatment to child protective services (CPS) are one important measure of prevalence of maltreatment. In 2015,^7^ CPS received 4 million referrals for suspected abuse or neglect, representing 7.2 million children (53.2 per 1,000 children). Among the 44 States reporting screened-in and screened-out referrals, 58.2 percent of referrals (3.4 million children) were screened in (that is, the referral was retained for further attention and received a CPS report). A subset of screened-in referrals was identified as victims of abuse or neglect: approximately 683,000 victims in 2015 (national victimization rate of 9.2/1,000). Children may have suffered multiple forms of maltreatment or may have experienced multiple instances of maltreatment. Of those with referrals, 75.3 percent experienced neglect, 17.2 percent experienced physical abuse, 8.4 percent experienced sexual abuse, 6.9 percent experienced other abuse, 6,2 experienced psychological abuse, and 2.2 experienced medical neglect.

Young children are the most vulnerable. As many as 24.2 per 1,000 children in their first year of life were identified as victimized. Rates of substantiated victimization were higher for girls (9.6/1,000) than for boys (8.8/1,000). African American children are nearly twice as likely to be substantiated victims of maltreatment reports (14.5/1,000) than whites (8.1/1,000) or Hispanics (8.4/1,000). American Indians are also at higher risk for substantiated victimization than whites (13.8/1,000).^8^ In 2015, 1,670 children died as a result of abuse or neglect (2.25 per 100,000 children).^9^

Although reports, investigations, and substantiated victims are one important way to understand the prevalence of maltreatment, not all acts of maltreatment are reported to authorities. All 50 States report cases of abuse and neglect to the National Center National Child Abuse and Neglect Data System, but definitions and rules for reporting vary by State and child protective service agency, and participation, being voluntary, is influenced by resource availability.^10^ The National Incidence Study, an approximately decennial sentinel respondent study last completed in 2005–2006, reported that 1.25 million victims (17/1,000) were harmed by maltreatment (harm standard), and nearly 3 million children were at risk of harm from maltreatment (40/1,000 by the endangerment standard).^11^

In addition to concerns about underreporting, some investigators have raised concerns regarding racial bias versus higher risk in explaining the disproportionate reporting of maltreatment of African American children. Investigations that explore these competing hypotheses of racial bias and higher risk emphasize a complex pathway between child maltreatment and poverty, with patterns varying by racial and ethnic groups, but they also note that these findings do not rule out racial bias.^12,^ ^13^

Ultimately, child maltreatment is often a private act known only to the perpetrator and the victim. Estimates of maltreatment can be derived from adolescent self-report, young adult self-report, or parent self-report, although surveys may yield wide variation in estimates based on the methods used such as different sampling frames, modes of assessment, and confidentiality and privacy assurances. Youth participants in the National Longitudinal Study of Adolescent Health self-reported victimization at much higher rates compared with the National Incidence Study. The former cites 28 percent reporting physical assault; 12 percent, physical neglect; 5 percent, contact sexual abuse; and 42 percent, supervision neglect. The 2013-14 National Survey of Children’s Exposure to Violence, a representative sample of U.S. telephone numbers, reported that 15.2 percent of 4,000 children and adolescents reported maltreatment by a caregiver.^14^

### Etiology and Natural History

Etiology and natural history characteristics reported below reflect only known cases of childhood maltreatment. Characteristics of those with maltreatment mostly have come from children in the social services system; those reported to CPS or police; or, in some instances, those who have reported maltreatment on a survey either conducted during childhood or reflecting back on child maltreatment as an adult.^15,^ ^16^

The etiology of childhood maltreatment can be organized into an ecological framework^17^ of different systems such as parent factors^18^ (genetic factors or social influences^19^), child factors viewed as bidirectional influences whereby a child’s behavior shapes parental responses^20,^ ^21^ (e.g., children with disability^22–24^), and social context factors such as attributes of the community or neighborhood that shape the way parents and children interact.^25–27^ Sometimes the social context factors are split into separate community and society factors.^28^

Maltreatment in early childhood is associated with negative physical and emotional health outcomes that persist and can escalate to serious disorders throughout the life course.^29–33^ Injuries may include brain injuries, blindness, and fractures.^34^ Injuries from abuse may lead to disability or death.^35^ Outcomes for children with maltreatment differ by the duration and severity of the maltreatment. They also differ by child characteristics such as age when maltreated, level of resiliency, and co-occurring parental issues such as mental health problems, substance abuse, and violence.^36,^ ^37^

For the child victim and into adulthood, child maltreatment has been linked to numerous short- and long-term morbidities. These can include attachment and behavioral problems; cognitive impairment; mental health disorders; violence^38–41^ and criminal behavior;^42^ physical health problems; and health risk behaviors such as substance use, obesity, and smoking.^43–45^ Sexual abuse can lead to sexual risk-taking behaviors that result in unplanned and unwanted pregnancy, sexually transmitted disease, and serious behavioral and emotional consequences.^46,^ ^47^ Abuse and neglect are also associated with impairments in cognitive development, executive functioning, and school performance. Exposure to the chronic stress of maltreatment can affect brain circuitry and hormonal system balances, which is particularly harmful during early childhood, when the brain is still developing at a rapid rate.^48,^ ^49^

Neglect can be as damaging as overt physical abuse.^50^ Neglected infants may not receive adequate nutrition or medical care and may be at higher risk of failing to thrive and developing infections;^51^ neglect is involved in a majority of child maltreatment deaths.^52^ Children in foster care may experience abuse, neglect, and multiple instances of caregiver loss that can lead to serious emotional and behavioral consequences.^53,^ ^54^ Adverse childhood experience can also have long-term negative consequences on adult education, employment, and income potential.^55^

Chronic and severe abuse and neglect are recognized as forms of complex trauma in that they represent “multiple traumatic events, often of an invasive, interpersonal nature … [with] wide-ranging, long-term impact … [that] usually begin early in life and can disrupt many aspects of the child’s development and the very formation of self.”^56^ As a result, children with complex trauma tend to be at higher risk for various mental and physical health problems across the life span. The total lifetime cost of all new cases of fatal and nonfatal cases of child maltreatment in the United States in 2008 was estimated to be $124 billion.^57^

### Risk Factors

No single risk factor exists for maltreatment. Some children will be maltreated with only a single risk factor, and others not until several different risk factors interact. In addition, risk factors for maltreatment may vary by the age of the child. Thus, the presence of known risk factors does not guarantee that maltreatment will occur; it only increases the risk that maltreatment might occur.^58^

Risk factors range from parental factors and child factors to societal factors pertinent to whole neighborhoods and communities. Parent risk factors of childhood maltreatment include domestic violence, poor parenting or communication skills, raising a child alone (single parenthood), nonbiological and transient caregivers, young age, poor educational attainment, low income, large number of children, parental history of maltreatment, substance abuse,^59^ and social isolation.^28,^ ^60^ Child risk factors include young age (less than age 4, particularly for neglect), special needs, sex, and having a history of child abuse.^28,^ ^61,^ ^62^ Societal factors include poverty, community and neighborhood violence, local unemployment rates, and weak social networks within communities.^63,^ ^64^

More recent research also has focused on the factors that prevent or mitigate the risk of childhood maltreatment. These protective factors are believed to increase child or parent resilience to risk exposure, strengthen families, strengthen connections with peers and community members, and enhance social and environmental conditions. Child protective factors include intelligence, good health and self-esteem, good relationships (peer, family, and friend) and social skills, having an optimistic disposition, good self-regulation or an easy temperament, having an active coping style, an internal locus of control, and a balance between seeking help and autonomy. Parental protective factors include nurturing caregiving; healthy parent-child attachment; parental knowledge of parenting and child development; parental coping skills; being part of a supportive, two-parent household with household rules and strong monitoring practices of children’s behavior; higher education attainment and extended family support; and making peace with their own childhood history of abuse.^65–67^ In addition, parents with supportive friends who have their basic needs met are less likely to perpetrate maltreatment. Social and environmental protective factors include neighborhood-level middle to high socioeconomic status, adequate housing, good schools, easy access to health care and social services, and supportive adults outside the family who can serve as role models or mentors to children in the community.

### Rationale for Intervention

Routine interventions to prevent child maltreatment could potentially reduce exposure to abuse and neglect, improve well-being, and reduce mortality. The focus of this review is on interventions relevant to primary care that are directed at the general population or at high-risk groups without signs and symptoms of maltreatment. The goal of such steps is preventing abuse or neglect from occurring.

### Types of Interventions

No established taxonomy exists for interventions that focus on preventing the first incidence of abuse and are relevant to primary care (i.e., they can be conducted in primary care settings or primary care providers can refer patients to appropriate settings). Interventions often attempt to mitigate risk factors and enhance protective factors. Interventions may be implemented in different settings, including the home, newborn nursery, and primary care; school; and community-based settings. They may include parenting programs, comprehensive parent education and support programs, and psychotherapy. Some common interventions include home interventions, pediatric primary care programs, psychotherapy programs, parent education, and community-based programs (Table 1).

Table 1 Types of Child Maltreatment Prevention Programs

Type of Program | Description of Program
Home visitation programs | - Aim to improve parenting and parent-child relationships by building positive parent-child relationships and attachment, reducing harsh parenting, increasing nurturing parenting, and improving safety in the home.; - Components may support parents in meeting basic needs (e.g., employment) and help them gain access to social support and community services.
Pediatric primary care programs | - Train health professionals to identify risk factors placing infants or children at high risk for maltreatment or neglect and to make referrals to community resources.; - Components include comprehensive parent education and support interventions.
Psychotherapy interventions | - May target high-risk groups.; - May focus on improving the parent’s mood and coping skills, using cognitive behavioral therapy strategies.; - Components include strengthening the parent-child relationship and addressing attachment problems between caregiver and child.; - May be offered in the home as a home visiting service, included as a component of a home visitation program, or be clinic-based.
Respite care programs | - Offer short-term, temporary relief to families caring for children with developmental disabilities or serious emotional disturbances that place them at risk for maltreatment or neglect.; - Offer families a break while providing a safe environment for the child.; - May be provided for several hours, overnight, or for a few weeks at a time and may be provided in the home, a foster home, or a facility in the community.
Parent education programs | - Improve parents’ understanding of children’s developmental needs and normal developmental behaviors, improving their capacity to provide nurturing care and increasing the use of positive discipline strategies.; - Are often didactic and delivered via parent groups.
Community-based programs | - Aim to reduce barriers created by a lack of community support and other negative forces within a community by both reducing risks and enhancing protective factors.; - Components include fostering partnerships with other local programs serving young children and working to create more supportive relationships among community residents.; - May also include achieving policy-level changes that increase resources available at the level of clinical care.

### Recommendations and Clinical Practice in the United States

Existing guidelines either recommend against screening for child maltreatment because of the risk of false positives or mislabeling,^68^ note insufficient evidence,^69^ or make no statement on screening^70^ (Appendix A2). Guidelines vary substantially in their confidence in interventions to prevent child maltreatment. The American Academy of Family Physicians agreed with the USPSTF’s position of insufficient evidence to recommend preventive interventions in a clinical setting to prevent child maltreatment in children without signs and symptoms of maltreatment. The American Academy of Family Physicians’ statement nonetheless describes a list of steps that primary care physicians can take to try to prevent maltreatment. Other guideline groups recommend home visitation programs.^68,^ ^70^ The American Academy of Pediatrics strongly recommends physician involvement in preventing child maltreatment^71,^ ^72^ and supports early childhood home visiting programs.^73^ No national surveys track practice patterns for preventive interventions, although a few studies address practice patterns for those treating children who have experienced maltreatment.^74–76^

Although the Centers for Disease Control and Prevention’s Community Guide^70^ and its supporting systematic review^77^ concluded that home visiting programs had strong evidence of effectiveness in preventing child maltreatment, other systematic reviews have not been as supportive, and have cited equivocal results. Reviews cite concerns about methods, surveillance bias, selective outcome reporting, validity and reliability of outcomes, and failure to address underlying heterogeneity in programs.^78,^ ^79^ One review that explored underlying heterogeneity of program components found that no single component predicted success.^78^ However, they concluded that alignment between underlying theory and program components, combined with a match between theory and target populations, explains program success.^78^

### Clinical Considerations for the Update

This updated review continues to be specific to populations that have not experienced maltreatment. It does not, however, require that eligible populations be at risk for maltreatment, because of the underlying variability in and lack of strong evidence supporting risk assessment tools.