# Appendix F Supplementary Results

## Appendix F1 Characteristics of Studies by Outcome

### Child Protective Services Reports

Fourteen fair- or good-quality studies reported on CPS outcomes.^89–91,^ ^93,^ ^95,^ ^98,^ ^103,^ ^104,^ ^107–109,^ ^111,^ ^113,^ ^114,^ ^117^ Seven of them were not included in the 2004^181^ or 2013^1^ report for the USPSTF.^95,^ ^103,^ ^107,^ ^111,^ ^113,^ ^114^ All studies identified in the previous review were evaluated for inclusion in this update, but two were excluded because of poor quality.^134,^ ^145,^ ^146^

Seven of the 14 included trials recruited participants during pregnancy or immediately after birth.^89–91,^ ^98,^ ^104,^ ^113,^ ^114^ The other seven trials either included a subset of participants recruited in the perinatal period or focused recruitment on families of infants or children. Four trials reported child maltreatment at baseline,^93,^ ^95,^ ^103,^ ^117^ although, in accordance with our inclusion criteria, no study had more than 50 percent of participants with substantiated reports. Other trials either did not specify prior experience of maltreatment or had participants who had not perpetrated or experienced maltreatment. Most trials (10 of 14) identified participants based on the risk of maltreatment, although the specific risk factors varied across studies.^91,^ ^93,^ ^98,^ ^103,^ ^104,^ ^108,^ ^109,^ ^111,^ ^113,^ ^114,^ ^117^ The other studies did not specify risk status or recruited from a low-risk population.^89,^ ^90,^ ^95,^ ^107^ In four studies, the majority of mothers were under the age of 20.^90,^ ^95,^ ^98,^ ^107^

All but one study^103^ included a home visiting component. The exception was a study set in a clinic for parents entering outpatient substance abuse treatment. Many (6 of 13) had clinical teams (nurses, psychologists) delivering the active intervention.^95,^ ^98,^ ^103,^ ^113,^ ^117^ Nearly all studies included a usual-care arm, with one exception, which compared active treatments for alcohol abuse, with or without parent skills training.^103^

All but three were based in the United States; the exceptions were set in the United Kingdom^90,^ ^104^ and New Zealand.^108,^ ^109^ Three were primarily clinic-based interventions.^89,^ ^103,^ ^113^

### Removal of Child from Home

Five studies, one good-quality trial^112^ and four fair-quality studies,^104,^ ^105,^ ^113,^ ^118,^ ^119^ reported on child removal outcomes. Four trials identified in the 2013^104^ or 2004^104,^ ^113,^ ^118^ previous review are included in this update. We identified one new fair-quality study not summarized in the previous reviews, published in 2003,^119^ and a second article^105^ that was published in 2009 reporting outcomes of a study included in the 2013 review.^104^

Four studies recruited women during pregnancy,^104,^ ^105,^ ^112,^ ^118,^ ^119^ and one recruited mothers of very low birthweight infants postpartum.^113^ One study sample comprised only first-time, adolescent mothers,^119^ and one study predominantly comprised mothers under age 20 years.^118^ One trial recruited only low-income participants (<200% Federal poverty limit FPL),^112^ whereas the other three trials were with conducted with a predominantly low-income population.^104,^ ^105,^ ^113,^ ^119^ In three studies, the majority of participants were single mothers.^112,^ ^113,^ ^118^ Two of the five studies reported that mothers had previous involvement with CPS,^112,^ ^118^ and neither study had more than 50 percent of participants with substantiated reports. All five studies screened and selected participants based on the presence of demographic risk factors associated with child maltreatment,^104,^ ^105,^ ^112,^ ^113,^ ^118,^ ^119^ with risk factors varying by study.

One study evaluated a comprehensive prenatal and pediatric program,^112^ and four studies evaluated home visiting interventions.^104,^ ^105,^ ^113,^ ^118,^ ^119^ Four of the five intervention approaches involved a multidisciplinary clinical team.^112,^ ^113,^ ^118,^ ^119^ The prenatal and pediatric program, which was clinic based but included home visits in some cases following missed appointments, was provided through the child’s second birthday.^112^ The home visiting interventions varied in duration, intensity, and timing: weekly, biweekly, then monthly visits beginning prenatally through 12 months postpartum;^118^ weekly home visits beginning at 6 months postpartum and provided up to18 months postpartum^104,^ ^105^; five home visits from birth through 18 months postpartum, supplemented by nurse consultation while the infant was in the hospital and weekly phone contact during the first 8 weeks postpartum;^113^ and five home visits during the first 4 months postpartum.^119^

All five trials compared the active intervention to routine care. The context for the routine care varied: in one study, both arms were conducted in high-risk groups, so the control was also characterized as a “high-risk control.”^112^ In a second study, early discharge interventions for very low birthweight infants were compared with routine care.^113^

The studies varied in their definitions of and data sources for evaluating removals. Three of the five trials used child welfare and/or court data documenting removal and placement in out-of-home care.^104,^ ^105,^ ^112,^ ^119^ One trial included both removal of the child’s siblings or the target child as the outcome but did not specify sibling or target child in reporting the outcome.^112^ Similarly, another trial defined removal as placement in foster care with or without the mother or due to the mother’s incarceration but did not specify this data in reporting outcomes.^119^ Another study assumed removal had occurred if a child’s records showed substantiated child abuse or neglect but did not gather documentation on removal per se.^104,^ ^105^ The two trials that did not report child welfare or court records as data sources either relied solely on mothers’ self-report^118^ or provided no information.^113^ Additionally, although one of these studies^118^ reported the number of children in foster care at followup, specific data on how many children had been removed prior to the study was not provided.

All trials focused on outcomes during the first 3 years of the child’s life, each with assessment at different time points: at birth and at 6 months,^118^ 6 months with removal data for the period between 6 months and 12 months also reported,^119^ 12 months (assessing the period between the 6-month and 12-month assessment time points),^104,^ ^105^ 18 months,^113^ and 36 months^112^ after the study child’s birth.

Three studies were set in the United States,^112,^ ^113,^ ^118^ one in the United Kingdom,^104,^ ^105^ and one in Australia.^119^ One intervention was provided primarily in the clinic.^112^

### Other Measures of Abuse or Neglect

Two RCTs, of good^112^ and fair^106^ quality, respectively, reported on study-specific measures of neglect. The good-quality study randomized 314 pregnant women in Metropolitan Nashville General Hospital (1984 to 1986) with income less than 200 percent of the Federal poverty level who were identified to be at high risk of maltreatment based on responses to a structured interview, the Maternal History Interview-2.^112^ The interview included questions on knowledge of parenting skills, philosophy about discipline, personality, positive and negative feelings about pregnancy, and the mother’s perception of her nurture as a child. The study randomized women to a comprehensive primary care intervention or usual care. The primary care intervention included prenatal, postnatal, and pediatric care, provided for 2 years by a multidisciplinary team including nurse midwives, nurse practitioners, social workers, paraprofessional home visitors, a nutritionist, and a psychologist. Abuse and neglect were identified based on review of public agency documents from the Tennessee Department of Human Services through 36 months of age. Specifically, abuse was defined as “hitting with the hand or objects, biting, burning with objects or by immersion, twisting, shaking, throwing or pushing so as to cause a fall, or hair pulling.” Neglect could arise from “abandonment, leaving a child with an inappropriate caretaker, gross failure to seek medical care, failure to provide shelter or nutrition, or gross failure to provide for normal intellectual development.”

The fair-quality study randomized 147 families of children born at medical risk (preterm or with a medical condition) in California; 87 percent of the families were Latino. The study compared a cognitively based extension of the Healthy Start home visitation program with a home visitation condition that did not include a cognitively based component.^106^ In the intervention arm, the parents learned to recognize children’s distress and learned problem-solving techniques. The neglect measure, reported at 1 year following intake, was based on the Framingham Safety Survey, which included questions about exposed electrical outlets, crib sides left down, and the presence of windows lacking screens.

### Injuries with a High Specificity for Abuse or Neglect

One fair-quality study reported on the risk of injury with a high specificity for abuse or neglect. Specifically, this study of pregnant Australian adolescents examined the effect of home visits versus usual care (1998 to 2000) on severe nonaccidental injury at 6 months. This outcome was defined as hospital admission as a result of an injury that was “referred for independent investigation by the Family and Children’s Services staff and concluded to have arisen as a result of a nonaccidental injury to the neonate.”^119^

### Emergency Room Visits

Eleven fair- or good-quality studies reported on ED visits.^89–92,^ ^96–102,^ ^104,^ ^105,^ ^108–110,^ ^113–116,^ ^120,^ ^121^ We did not include studies that reported measures that could potentially have included nonemergency care (“acute care visits” that did not specify whether these were ED visits^113^). Six of the identified 11 studies were included in the earlier reviews.^89,^ ^91,^ ^92,^ ^96–102,^ ^104,^ ^108,^ ^109^

Nine of the 11 fair- or good-quality trials recruited participants during pregnancy or immediately after birth.^89–92,^ ^96–102,^ ^104,^ ^105,^ ^110,^ ^113–116^ Two of the included trials recruited participants in early infancy.^108,^ ^109,^ ^120,^ ^121^ None of the studies reported on child maltreatment at baseline. Nine of the 11 trials identified participants based on the risk of maltreatment with specific risk factors varying across the studies.^89,^ ^91,^ ^92,^ ^96–102,^ ^104,^ ^105,^ ^108–110,^ ^113,^ ^114,^ ^120,^ ^121^ The remaining trials randomized all newborns at the study site regardless of baseline risk for maltreatment.^90,^ ^115,^ ^116^ One study specifically targeted very low birth weight infants.^113,^ ^114^ In three studies, the majority of all mothers were under age 20 years.^90,^ ^96–102^

All studies included a home visiting component. Home visits ranged from 4 weeks to 5 years postnatally. The study of very low birth weight infants paired early discharge and home visits.^113,^ ^114^ All studies had a usual-care arm, except one that provided transportation to and from prenatal clinic visits to the control group.^96,^ ^97^ Six of the 11 studies had multiple active comparisons against the usual-care arm.^89,^ ^96–102,^ ^110,^ ^114,^ ^120,^ ^121^

Seven of the 11 studies were based in the United States. The exceptions were three studies set in the United Kingdom,^90,^ ^104,^ ^105,^ ^120,^ ^121^ one in New Zealand,^108,^ ^109^ and one in Canada.^98–102,^ ^110^ Two used a combination of parental report and medical record data,^89,^ ^114^ and three fair- or good-quality studies used parental report only.^104,^ ^105,^ ^110,^ ^120,^ ^121^

Seven of 11 included studies reported ED visit outcomes at 1 to <2 years after enrollment or recruitment.^89,^ ^90,^ ^98–102,^ ^104,^ ^105,^ ^110,^ ^114,^ ^120,^ ^121^ Two of these studies reported only medical record data.^90,^ ^98–102^ Two used a combination of parental report and medical record data,^89,^ ^114^ and three fair- or good-quality studies used parental report only.^104,^ ^105,^ ^110,^ ^120,^ ^121^

Six of 11 included studies reported ED visit outcomes at 2 to >4 years of followup.^90–92,^ ^96–102,^ ^108,^ ^109,^ ^115,^ ^116^ With one exception^115,^ ^116^ outcomes were taken from medical records.

### Hospitalization

Twelve fair- or good-quality studies reported on hospitalization outcomes.^89–92,^ ^96,^ ^99,^ ^104,^ ^108,^ ^109,^ ^113,^ ^114,^ ^116,^ ^119,^ ^121^ We included five trials not previously summarized in the 2004^181^ or 2013^1^ reports.^113,^ ^114,^ ^116,^ ^119,^ ^121^ and two studies published since 2013,^90,^ ^109^ one of which^109^ reports 9-year followup outcomes of a study included in the last review.^108^

Ten of the 12 fair- or good-quality trials recruited all participants during pregnancy or immediately after birth.^89,^ ^90,^ ^96,^ ^99,^ ^104,^ ^113,^ ^114,^ ^116,^ ^119,^ ^121^ Other fair- or good-quality trials focused recruitment on families of infants or children, often identified as high risk during the prenatal or perinatal period.^91,^ ^92,^ ^108,^ ^109^ One trial reported child maltreatment at baseline,^96^ although, in accordance with our inclusion criteria, no study had more than 50 percent of its sample with identified maltreatment, including CPS involvement, at baseline. Other trials either did not specify prior experience of maltreatment or had participants who had not perpetrated or experienced maltreatment. Most trials (7 of 12) identified participants based on the risk of maltreatment, although the specific risk factors varied across studies.^91,^ ^92,^ ^96,^ ^99,^ ^104,^ ^108,^ ^109,^ ^113,^ ^114^ The other studies did not specify risk status or recruited from a low-risk population.^89,^ ^90,^ ^116,^ ^119,^ ^121^ In four studies, the majority of or all mothers were under age 20 years.^90,^ ^96,^ ^119^

All but two studies^89,^ ^116^ included a home visiting component. Many (8 of 12) had clinical teams delivering the active intervention.^90,^ ^96,^ ^99,^ ^108,^ ^109,^ ^113,^ ^116,^ ^119,^ ^121^ All studies included a usual-care arm. Five studies had multiple active comparisons against the usual-care arm.

All but five studies were based in the United States; the exceptions were three set in the United Kingdom,^90,^ ^104,^ ^121^ one in New Zealand,^108,^ ^109^ and one in Australia.^119^ Three were primarily clinic-based interventions.^89,^ ^113,^ ^116^

### Failure to Thrive

One fair-quality trial of early discharge with nurse home visits for very low birthweight infants recruited from the Hospital of the University of Pennsylvania (1982 to 1984) reported on failure to thrive (N=72 mothers and 79 infants).^113^ Mothers of infants weighing ≤1,500 g were randomized to early discharge followed by home visits or routine nursery policy. The early-discharge group received nurse home visits in the first week and at 1, 9, 12, and 18 months; regular telephone contact for 8 weeks; and an on-call nurse specialist backed up by a neonatologist. The usual-care group was discharged when the infant was approximately 2,200 g as long as the child was clinically well and feeding well. The study reported failure to thrive at 18 months.

### Failure to Immunize

One fair-quality study of pregnant Australian adolescents that examined home visits versus usual care (1998 to 2000) reported on the proportion with no vaccinations at 6 months.^119^

### Internalizing and Externalizing Behaviors

Six fair- or good-quality studies reported on internalizing and externalizing behavioral outcomes in children.^91–94,^ ^96,^ ^97,^ ^104,^ ^108,^ ^109,^ ^115–117^ The primary outcome measures used by most studies to assess behavior symptoms were the CBCL and the ITSEA. In addition to the CBCL and ITSEA, several other measures were used, including the Strengths and Difficulties Questionnaire, the Social Skills Rating System, and the Computerized Diagnostic Interview Schedule for Children.^96,^ ^97^

We identified one fair or good trial not previously summarized in the 2004 or 2013 report.^115,^ ^116^

Five of the six fair- or good-quality trials recruited participants during pregnancy or immediately after birth.^91–94,^ ^96,^ ^97,^ ^104,^ ^108,^ ^109,^ ^115,^ ^116^ One good-quality study recruited mothers of children ages 6 to 36 months.^117^ Three of the six fair- or good-quality trials reported child maltreatment at baseline,^93,^ ^94,^ ^96,^ ^97,^ ^117^ but no study had more than 50 percent of participants with substantiated reports of abuse or neglect. Other trials did not have participants with a history of maltreatment. Five of six fair- or good-quality trials identified participants based on risk of maltreatment.^91–94,^ ^104,^ ^108,^ ^109,^ ^115,^ ^117^ One fair-quality study^115,^ ^116^ offered services to all families in a primary care setting regardless of vulnerability. For five of the six fair- or good-quality studies, most or all of the mothers were under age 20 years.^91–94,^ ^96,^ ^97,^ ^104,^ ^108,^ ^109,^ ^117^

All of the six fair- or good-quality trials included a home visiting component.^91–94,^ ^96,^ ^97,^ ^104,^ ^108,^ ^109,^ ^115,^ ^116^ Four of the six trials were conducted by clinical teams delivering the actual intervention.^96,^ ^97,^ ^108,^ ^109,^ ^115–117^ All of the studies included a usual-care arm or no treatment group comparator.

All but two of the studies were based in the United States; one study took place in New Zealand.^108,^ ^109^ One fair-quality study took place in a primary care setting with a home visiting component.^115,^ ^116^

Four fair- or good-quality studies reported on behavior symptoms using the Internalizing and Externalizing Scales of the CBCL^91–94,^ ^96,^ ^97,^ ^115,^ ^116^; two fair- or good-quality studies reported on internalizing and externalizing behavior problems in children using the ITSEA.^108,^ ^109,^ ^117^ One study also used the Strengths and Difficulties Questionnaire.^108,^ ^109^ One study later used the Computerized Diagnostic Interview Schedule for Children to assess for behavior symptoms.^96,^ ^97^

### Social, Emotional, and Developmental Outcomes Not Otherwise Categorized

Five studies evaluated discrete social, emotional, or other developmental outcomes separately from overall measures of externalizing or internalizing problems.^94,^ ^97,^ ^104,^ ^105,^ ^115–117^ Two were good-quality trials,^94,^ ^117^ and three were fair-quality studies.^97,^ ^104,^ ^105,^ ^115,^ ^116^ Four studies identified in the previous 2013 review^93,^ ^97,^ ^104,^ ^117^ are included in this update. We identified one new fair-quality trial^115,^ ^116^ and one final evaluation report^94^ of a study previously included in the 2013 review.^93^

Two studies recruited women during pregnancy,^97,^ ^104^ one study recruited women during pregnancy or up to 4 months postpartum,^93,^ ^94^ one study recruited families of newborns up to 4 weeks of age,^115,^ ^116^ and one study recruited mothers of children between the ages of 6 and 36 months.^117^

Two studies were conducted with a predominantly low-income population;^97,^ ^104,^ ^105,^ ^117^ the other two studies had a socioeconomically mixed population.^93,^ ^94,^ ^115,^ ^116^ One study sample was predominantly African American.^97^ Three trials had study samples comprised predominantly of single mothers.^93,^ ^94,^ ^97^ One study actively recruited first-time pregnant adolescents under the age of 19 years but also admitted other pregnant women into the study.^97^ Two trials included mothers with a previous history of CPS involvement, which met the threshold for inclusion in this review.^93,^ ^94,^ ^117^ Three trials screened and selected participants based on level of risk, either for child maltreatment^93,^ ^94^ or on general sociodemographic and psychosocial risk and/or the presence of child social-emotional/behavioral problems.^97,^ ^104,^ ^117^

Four studies evaluated home visiting models that focused on intervening for a substantive period starting before and/or during some portion of the child’s first 3 years and that varied on frequency, intensity, and duration.^93,^ ^94,^ ^97,^ ^104,^ ^105,^ ^117^ One program initiated visits with children between the ages of 6 and 36 months, providing 12 months of weekly home visits, with the number of visits individualized based on participants’ needs (an average of 22 visits during a 1-year period).^117^ One trial evaluated a 2-year intervention program that began during pregnancy and provided home visits through the child’s second birthday (an average of 22 home visits during a 2-year period).^93,^ ^94^ One home visiting study evaluated a program that began during pregnancy and provided biweekly home visits through the child’s second birthday.^97^ A fourth home visiting trial evaluated a program of weekly visits beginning 6 months postpartum and provided up to 18 months postpartum.^104,^ ^105^ One trial evaluated an enhanced pediatric well-child care model that provided families with a developmental specialist and multiple services including up to six home visits during the child’s first 3 years, including developmental assessments, written materials, parent groups, and linkages to community resources.^115,^ ^116^ Two trials used a clinical team in the intervention approach;^115–117^ one of these interventions involved a developmental and mental health specialist teaming with a paraprofessional, reflective of the ethnic and cultural diversity of the family, providing care coordination.^117^ One study intervention was delivered solely by nurses,^97^ another by community midwives,^104,^ ^105^ while another intervention relied on trained paraprofessionals.^93,^ ^94^

Three of the five trials compared the active intervention to usual care.^104,^ ^105,^ ^115–117^ One study^97^ randomized participants into four arms: free transportation to prenatal care appointments (group 1); development screening and referral services for the child at 6, 12, and 24 months plus free transportation for prenatal care (group 2); nurse visitation during pregnancy, one postpartum visit in the hospital before discharge, one postpartum visit in the home plus group 2 services (group 3); and nurse visitation through the child’s first 2 years of life plus group 3 services (group 4). The study then combined groups 1 and 2 for the comparator group. Another study provided control group participants with information and referrals to other appropriate services in the community.^93,^ ^94^

Each of the five studies reported different social, emotional, or other developmental outcomes that fell outside the categories of externalizing or internalizing behavior or that were combined with internalizing and/or externalizing outcomes in their measurement. One trial examined dysregulation (i.e., problems with sleep, eating; sensory sensitivities; negative emotionality) as an outcome.^117^ Another study reported on children’s sleep problems^115^ and social skills (i.e., positive social behaviors such as cooperation, empathy, assertion, and self-control; externalizing, internalizing, and hyperactivity problem behaviors; and academic competence).^116^ A third trial evaluated outcomes using the attention and social problems subscales of a measure used to assess problem behavior;^93,^ ^94^ this study also reported these outcomes for a subgroup of young, first-time mothers who engaged in the program prenatally. A fourth trial examined children’s conduct problems (1^st^ to 3^rd^ grade), antisocial behavior, academically focused behavior, and peer affiliation using either school records or teacher reports and teacher structured observation.^97^ One study included a measure of infant/toddler social and emotional adjustment but did not report any specific outcomes associated with that measure;^104^ however, a subsequent cost evaluation of the trial^105^ reported generally on outcomes.

The timing of assessments varied considerably across the studies, with three studies reporting long-term followup results.^94,^ ^97,^ ^116^ One trial reported outcomes at 6 and 12 months post-baseline assessment.^117^ One trial assessed outcomes at 12 months into an 18-month intervention (reflecting the period between the 6-month and 12-month time points).^104,^ ^105^ One study evaluated outcomes close to the end of the 3-year intervention period (when children were 30 to 33 months old).^115^ The studies evaluating longer-term effects reported outcomes at different developmental and followup time points: 5 to 5.5 years (approximately 2 years post-intervention completion),^116^ 7 years (5 years post-intervention completion),^94^ and 9 years (7 years post-intervention completion).^97^

Four studies were set in the United States.^93,^ ^94,^ ^97,^ ^115–117^ One study was conducted in the United Kingdom.^104,^ ^105^

### Child Development as Measured by the Bayley Scales of Child Development

Four fair- or good-quality studies reported on child development as measured by the Bayley Scales of Child Development.^91,^ ^92,^ ^96–102,^ ^104^ In addition, three poor-quality studies reported on child development as measured by the Bayley Scales of Child Development.^145,^ ^146,^ ^174,^ ^177^ All previous studies were included in this update, although one was changed from a good-quality rating to a fair-quality rating^98–102^ and another was changed from a fair-quality to poor-quality rating.^145,^ ^146^ In both cases, these changes were due to deviations from the intervention.

We identified two poor-quality trials not previously summarized in the 2004 or 2013 review.^174,^ ^177^ One good-quality trial had been summarized previously, but the outcomes related to the Bayley scales had not been included in previous reviews.^91,^ ^92^ Of these, none had been published in 2013 or later.

All four of the fair- to good-quality studies recruited participants during pregnancy or immediately after birth.^91,^ ^92,^ ^96–102,^ ^104^ None of the studies reported child maltreatment at baseline, though two of the fair-quality studies specifically recruited first-time mothers.^96–102^ The four fair- to good-quality studies did identify participants based on risk factors, though different risk factors were used.^91,^ ^92,^ ^96–102,^ ^104^ Two studies had a majority of mothers who were under age 20.^96–102^ Another study had about 20 percent of mothers who were under age 17.^104^

All studies included a home visiting component. This was compared to usual care,^104^ transportation to appointments,^96^ referral to other services,^92^ and developmental screening for the child at 1 and 2 years of age.^98^ One study compared a group consisting of participants who got developmental screening at 1 and 2 years of age with or without transportation assistance to two active comparison groups.^98^ The two active comparison groups in this study got the developmental screening and transportation assistance as well as prenatal visits for one of the active comparison groups and prenatal and postnatal visits for the other active comparison group.

One of the studies was in the United Kingdom,^104^ and the others were in the United States.

### Other Development Outcomes

Three fair-quality studies reported on other outcome measures.^90,^ ^98,^ ^116^ One study actively recruited pregnant women with characteristics that predisposed their children to poorer health and development problems (younger than 19 years, single-parent, low socioeconomic status) but also admitted other pregnant women into the study. The study randomized participants into four arms: sensory and development screening for children at 12 and 24 months (group 1), free transportation to regular prenatal and well-child visits plus group 1 services (group 2), nurse visitation during pregnancy plus group 2 services (group 3), and nurse visitation through the child’s first 2 years of life plus group 3 services (group 4). The study then combined groups 1 and 2 for the comparator group. The study reported mean scores on the Cattell Scale at 6, 12, and 24 months of age.^98^ A second study included both a randomized and quasi-experimental component (Healthy Steps for Young Children; 1996 to 1998); this review focuses on the randomized component comparing usual care with a comprehensive pediatric care model with developmental specialists, enhanced developmental services, and home visits. This study reported the proportion of parents with a significant concern regarding the child’s development on the Parents’ Evaluation of Development Status at 5 to 5.5 years of age.^116^ A third study randomized pregnant teenagers to a nurse home visiting program or usual care. The study reported the number of mothers with concerns on cognitive and language development and also reported results on an early language scale (Early Language Milestone Scale) for the child.

### School Performance: Overview of the Evidence

One study of fair quality^96,^ ^97^ reported on developmental outcome scores and school outcomes. One fair-quality trial^96^ of nurse prenatal and infancy home visits with mothers recruited from an obstetrical clinic at the Regional Medical Center in Memphis (1990 to 1991) reported on mental development (N=1,139 mothers).^96^ This study was previously included in the 2013^1^ report, but the results for school performance had not been previously reported. High-risk pregnant mothers less than 29 weeks’ gestation were randomized to one of four treatment conditions: Group 1: free transportation by cab to scheduled prenatal care appointments; Group 2: free transportation to prenatal care appointments plus developmental screening and referral services for the child at 6, 12, and 24 months; Group 3: free transportation and screening plus intensive nurse home visitation services during pregnancy, one postpartum visit in the hospital, and one postpartum visit in the home; or Group 4: all of Group 3 interventions plus nurse visits through the child’s second birthday. Treatment group 2 was contrasted with group 4 for the postnatal phase of the study. The study reported mental development scores on the Bayley Scales of Infant Development at 24 months. In a followup study,^97^ the children were evaluated again at 9 years of age (N=743). The study reported children’s grade point averages in reading and math and achievement test scores in grades 1 to 3.

### School Attendance: Overview of the Evidence

One good-quality study^93,^ ^94^ of home visiting, modeled after Healthy Families New York (HFNY), by paraprofessionals pre- and postnatally for high-risk infants recruited from a university hospital (2000 to 2001) reported on school attendance. This study was previously included in the 2013^1^ report, but the results for school performance had not been previously reported. Mothers of high-risk infants were randomized to HFNY or usual care. The HFNY group received an average of 22 home visits by trained paraprofessionals biweekly during pregnancy and once weekly after birth with a focus on promoting healthy behaviors and parent-child relationships, improving adherence to scheduled immunizations and well-child visits, and connecting with community resources. The usual-care group was provided with information and referral to other appropriate services in the community. The followup study^94^ reported on improved school attendance assessed by child and maternal reports of skipping school often at age 7 years.

### Death

Four studies of fair quality reported on the outcome of child death.^96,^ ^97,^ ^104,^ ^113,^ ^119^ All studies identified in the previous review are included in this review. We identified one fair-quality study not previously summarized in the 2004 or 2013 report.^119^ We identified one fair-quality study that was included in the 2004 review but not included in the 2013 review.^113^

All four fair-quality studies recruited all participants during pregnancy or immediately after birth.^96,^ ^97,^ ^104,^ ^113,^ ^119^ Only one fair-quality trial reported child maltreatment at baseline.^96,^ ^97^ Other trials did not specify experience of prior maltreatment. Three of the four studies identified participants based on risk of maltreatment, although the specific risk factors varied across studies.^96,^ ^97,^ ^104,^ ^113^ The other study recruited from a low-risk population.^119^ In two studies, the majority of or all mothers were under age 20 years.^96,^ ^97,^ ^119^

All four fair-quality studies included a home visiting component. Three had clinical teams delivering the active intervention.^96,^ ^97,^ ^113,^ ^119^ All four fair-quality studies included a usual-care arm.

Two of four fair-quality studies were set in the United States.^96,^ ^97,^ ^113^ The others took place in the United Kingdom^104^ and Australia.^119^

### Composite Outcome

One fair-quality trial of home visits by nurse midwives to teenage mothers recruited from an Australian public-care teenage pregnancy clinic (1998 to 2000) reported on a composite outcome of child abuse and neglect, which the study defined as the pooled incidence of infant death, severe nonaccidental injury, and involuntary foster care placement (N=136 adolescent mostly low-income mothers and infants).^119^ Participants were not identified to be at risk, and no baseline child maltreatment was reported. Mothers presenting for antenatal visits were recruited and then after delivery randomized to receive a set of postnatal visits from the nurse midwives at 1 week, 2 weeks, 1 month, 2 months, 4 months, and 6 months after delivery or not. Visits with the nurse midwives lasted 1 to 4 hours. The composite outcome was assessed at 6 months.

Appendix F Table 1 Contribution of Poor-Quality Studies to the Results

Outcome | Results From All Studies, Including Poor Quality
Reports to CPS | - Adding nine poor-quality studies^134,^ ^135,^ ^145–148,^ ^172,^ ^176,^ ^178,^ ^179^ to the pooled estimate of effect for first report of results from studies did not alter the direction of effect, although it improved the precision (OR, 0.84; 95% CI, 0.68 to 1.04, I^2^: 9.2%; Appendix F, Figure 1).; - Poor-quality studies reporting outcomes at multiple time points also did not find statistically significant results with repeated measures.^135,^ ^146^
Removal of the child from the home | - Adding three poor-quality studies to the pooled estimate altered the direction but not the precision of the results (RR, 1.51; 95% CI, 0.63 to 3.66; I^2^; 38.3%; 7 studies; N=1,779%; Appendix F, Figure 2).^135,^ ^145,^ ^146,^ ^169,^ ^177^
Injuries with a high specificity for abuse or neglect | - One poor-quality study found no differences.^173^
ED visits | - One poor-quality study reported no statistically significant differences in the number of children seen in the ED when comparing study arms in the first year.^145^; - One poor-quality study reported the total number of ED visits at 12 months (without means or standard deviations); the study noted no statistically significant results.^171,^ ^175^; - One poor-quality study reported no difference in the number of times a newborn was taken to the ED.^134^; - Three poor-quality studies reported number of children using the ED after the second year^145,^ ^146,^ ^171,^ ^175,^ ^179^; of these, one found statistically significant results (calculated RR, 0.72, 95% CI, 0.58 to 0.90).^171^; - One poor-quality study^178^ reported the absence of ED visits for injuries at 2 years and found no statistically significant difference between arms.; - Two studies reported numbers of ED visits; of these, one reported no differences^175^ and one did not report estimates of effect.^173^
Hospital izations | - Three of five poor-quality studies showed significant between-group differences in hospitalization outcomes among home visitation only^171^ and comprehensive primary care interventions with home visits.^135,^ ^173^; - Two poor-quality home visitation programs reported no difference.^145,^ ^146,^ ^174^
Failure to thrive | - One poor-quality study also did not find statistically significant differences between study arms.^135^
Failure to immunize | - Three poor-quality studies reported delayed immunizations,^148^ complete immunizations at 12 months for African American and Mexican infants,^177^ or no DPT or MMR immunization at 15 months.^174^; ○ One study found a significant lower risk of delayed immunizations at 3 years in the intervention arm when compared with the control arm (calculated RR, 0.34; 95% CI, 0.16to0.69).^148^; ○ A second study found no significant differences.^177^; ○ A third study found a statistically significant difference for DPT immunization only, for which the intervention arm had lower risk of incomplete immunizations (calculated RR, 0.31; 95% CI, 0.10to0.96).^174^
Internalizing and externalizing behaviors | - Two poor-quality studies found no difference in the number of children^176^ with or mean scores^172^ for internalizing or externalizing behavior.
Bayley development scales | - Three poor-quality studies reported on the Bayley index at 1 year of age.^145,^ ^174,^ ^177^; ○ Two of the three poor-quality studies reported the Bayley mental index and psychomotor index at 1 year of age.^145,^ ^177^ One study reported no significant difference in the mean scores in either index.^145^; ○ The other found no significant differences between the experimental and control groups for the Mexican American children in this study on either the motor index or mental index. For the African American children, although there was a statistically significant (p<0.05) difference between the experimental group and the control group on the Bayley mental index, there was no difference in the motor index. It is not clear that the study was powered to detect these subgroup differences, although it was specifically seeking participants from these two groups.^177^; - One poor-quality study reported the Bayley mental and motor scores at 15 months of age.^174^ The scores for the control and experimental groups were similar for the mental index and motor index in this study. For the mental index, the means were 115.5 (SD 7.0) for the experimental group (n=21) vs. 114.9 (SD 3.3) for the control group (n=26). For the motor index, the means were 118.4 (SD 8.8) for the experimental group vs. 114.2 (SD 13.2) for the control group. The authors do not comment on whether the Bayley scores themselves were statistically significantly different.; - One poor-quality study reported the Bayley mental index and psychomotor index at 2 years of age^145^ and reported no significant difference between the mean scores in either index in this study.
Other development outcomes (concern regarding child’s development) | - One poor-quality study also found no differences.^135,^ ^136^
Death | - One poor-quality study reported no deaths in either arm.^177^

Abbreviations: CI=confidence interval; CPS = child protective services; DPT=diphtheria, pertussis (whooping cough), and tetanus; ED=emergency department; I^2^=proportion of the observed variance that reflects variance in true effect sizes rather than sampling error; MMR=measles, mumps, and rubella; N=number; OR=odds ratio.

Appendix F Figure 1 Child Protective Services Reports: Sensitivity Analysis With Poor-Quality Studies

Abbreviation: CI=confidence interval.

Appendix F Figure 1 displays a forest plot of the odds ratios for having any Child Protective Services reports after participating in a child maltreatment preventive intervention from the 19 trials used in the sensitivity analysis. Meta-analysis of all 19 trials resulted in an odds ratio of 0.841 with a 95 percent confidence interval of 0.679 to 1.043. The I-squared for this analysis was 9.2 percent.

Appendix F Figure 2 Child Removal From the Home: Sensitivity Analysis With Poor-Quality Studies

Abbreviation: CI=confidence interval.

Appendix F Figure 2 displays a forest plot of the odds ratios for a child being removed from the home after participating in a child maltreatment preventive intervention from the 7 trials used in the sensitivity analysis. Meta-analysis of all 7 trials resulted in an odds ratio of 1.550 with a 95 percent confidence interval of 0.610 to 3.940. The I-squared for this analysis was 39.4 percent.

## Appendix F3 Contextual Question Related to Caregiver Self-Reported Measures of Potential for or Commission of Child Abuse and Neglect

We found 22 trials of interventions to prevent child maltreatment that reported on caregiver self-reported instruments measuring the potential for or commission of abuse or neglect.^91,^ ^93,^ ^98,^ ^103,^ ^106,^ ^108,^ ^109,^ ^111,^ ^116,^ ^134,^ ^145–148,^ ^157,^ ^158,^ ^161,^ ^182–186^ This evidence base includes four trials excluded from the main analysis because of high risk of bias, and six trials excluded from the review because they did not report any eligible outcomes.

These studies reported on several instruments. The most commonly reported outcome was the child conflict tactic scale (CTS), in either the traditional version or the revised version (10 studies).^91,^ ^93,^ ^106,^ ^108,^ ^109,^ ^147,^ ^148,^ ^158,^ ^182–184^ Investigators typically reported one or more subscales, combinations of items, and individual items on the CTS. Five studies reported on the Child Abuse Potential Inventory.^111,^ ^134,^ ^157,^ ^161,^ ^185^ Two studies reported items on the use^98^ or nonuse^184^ of use of force. One study reported on each of the following: Parenting Scale,^103^ Parent Screening Questionnaire,^147^ Mother–Child Neglect Scale (MCN), ^183^ and Parenting Practices Interview (PPI).^186^ The followup ranged from 6 months to 7 years.

Eight studies reported one or more statistically significant results from the CTS.^91,^ ^93,^ ^106,^ ^108,^ ^109,^ ^145–148,^ ^158,^ ^184^ The studies reported on various subscales or combinations of items from CTS: minor assault, corporal punishment, psychological aggression, harsh parenting, neglect, and severe or very severe physical assault.

Studies reporting on instruments other than CTS did not find any statistically significant results, with three exceptions. One study reported statistically significant differences in the never use of slapping hands for infants age 6 months to 1 year.^184^ One study reported a difference in the overreactivity subscale of the Parenting Scale, for fathers.^103^ One study reported a difference in the harsh discipline subscale of the PPI.^186^

For every outcome with a statistically significant result, the same study or other studies reported no differences, suggesting inconsistent and inconclusive evidence. The one study reporting never use of slapping hands also reported nonsignificant results for five other measures of use of force toward the child (all at 1 year).^184^ Another study reported no difference on the use of force at 6 months.^98^

One study found a difference at the 2-year followup in the use of corporal punishment in the past year,^91^ but not in the past week.^91^ One study found a difference in the use of corporal punishment for infants at 1 year,^106^ and a second found no differences at 5 to 5.5 years.^116^

Three studies reported on harsh parenting and all found one or more statistically significant difference, favoring the intervention arm.^103,^ ^108,^ ^109,^ ^158^ One of the three studies, however, reported measures of overreactivity for mothers and father separately at the 6- and 12-month followup; the statistically significant difference was at 12 months for fathers only.^103^

For minor assault, one study reported statistically significant results for minor assault at 12 months, but not at 6 months.^147^ Two other studies reported no differences for minor assault at 2 years^91,^ ^148^ or at 3 years.^148^

For psychological aggression, two studies found no differences at 6 months^183^ and 3 years,^148^ respectively, and one study found a difference at 2 years.^91^ Other studies were not consistent over time. One study found results favoring the intervention group for psychological aggression at the 1-year followup,^93^ but not at 2^93^ or 7 years.^94^ A second study found no difference at 6 months, but found differences at 12 months.^147^

For neglect, one study found statistically significant differences on the revised CTS but not the traditional CTS scale.^146^ Three other studies found no differences.^91,^ ^93,^ ^94,^ ^183^

Results for subscales for serious or very serious physical abuse were also inconsistent: two studies showed a difference in the prevalence and frequency of very serious physical abuse at 1^93^ and 3 years^148^ but one of two studies did not find an effect at 2 years^93^ or at a 7-year followup.^94^ A third study found no differences at 2 years.^91^

In summary, the preponderance of the evidence for parent-self-report of abuse or neglect (or the potential for abuse or neglect) does not demonstrate benefit for interventions to prevent child maltreatment. Of the 10 studies reporting one or more statistically significant outcome, 7 reported other nonsignificant results as well for other subscales, items, or time points. Because studies did not indicate whether one or more of these outcomes was specified a priori, the potential for reporting bias cannot be ruled out. Specifically, studies that reported only statistically significant results of subscales from the CTS did not specify whether this outcome had been selected a priori, and why results of the entire scale were not analyzed.^106,^ ^158^ Similarly, studies reporting a minority of statistically significant results alongside a much larger set of statistically nonsignificant results may have obtained those results by chance.

Appendix F Table 2 Parent Self-Reported Outcomes – Multiple CTS Subscales Combined, Categorical Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | Child Abuse or Neglect, G1 No. (%) | Child Abuse or Neglect, G2 No. (%) | Child Abuse or Neglect, G3 No. (%) | Child Abuse or Neglect, G4 No. (%) | Effect Estimate or Other Outcome Measure
Duggan et al, 1999^145^ Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Mother’s self-reported severe abuse and frequent psychological abuse or minor assault in Year 1; based on CTS, defined as severe or very severe physical abuse and reported using either acts of psychological aggression or minor physical assault more often than the sample median.^*^ | 1 year | NR (3) | NR (4) | NA | NA | NR^†^
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Mother’s self-reported severe abuse and frequent psychological abuse or minor assault in Year 2; based on CTS, defined as severe or very severe physical abuse and reported using either acts of psychological aggression or minor physical assault more often than the sample median.^*^ | 2 years | NR (6) | NR (7) | NA | NA | NR^†^
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Mother’s self-reported severe abuse and frequent psychological abuse or minor assault in Year 3; based on CTS, defined as severe or very severe physical abuse and reported using either acts of psychological aggression or minor physical assault more often than the sample median.^*^ | 3 years | NR (8) | NR (8) | NA | NA | AOR, 1.02 (95% CI, 0.61-1.71; p=0.94)^ǂ^
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=1,060) | Serious abuse and neglect composite scale per parent-child Conflict Tactics Scale (CTS-PC): prevalence | 1 year | NR (7.28) | NR (5.67) | NA | NA | p=ns
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=992) | Serious abuse and neglect composite scale per parent-child Conflict Tactics Scale (CTS-PC): prevalence | 2 years | NR (7.83) | NR (6.78) | NA | NA | p=ns

* This measure is used as the denominator to calculate recognition rates (rate of which home visitors recognize and respond to child maltreatment).

† Authors only reported adjusted odds ratio for the 3-year followup. Of families receiving a high dose of HSP services, 3%, 8%, and 5% mothers reported both frequent and severe abusive behavior in years 1, 2, and 3, respectively.

ǂ Of families receiving a high dose of HSP services, 3%, 8%, and 5% mothers reported both frequent and severe abusive behavior in years 1, 2, and 3, respectively.

Abbreviations: AOR=adjusted odds ratio; CI=confidence interval; CTS=Conflict Tactics Scales; CTSPC=Parent-Child Conflict Tactics Scales; G=group; N\n=number; NA=not applicable; NR=not reported.

Appendix F Table 3 Parent Self-Reported Outcomes – Multiple CTS Subscales Combined, Continuous Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | CTS Score, G1 Mean (SD) | CTS Score, G2 Mean (SD) | CTS Score, G3 Mean (SD) | CTS Score, G4 Mean (SD) | Effect Estimate or Other Outcome Measure
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=1,060) | Serious abuse and neglect composite scale per parent-child CTS-PC: frequency^*^ | 1 year | 0.53 (NR) | 0.27 (NR) | NA | NA | p=ns
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=992) | Serious abuse and neglect composite scale per parent-child CTS-PC: frequency^*^ | 2 years | 0.35 (NR) | 0.38 (NR) | NA | NA | p=ns

* All mean CTS scores are adjusted for prior substantiated reports of child abuse or neglect, 2 dummy codes representing race/ethnicity, random assignment at gestational age 30 weeks or less, site of participation, status as first-time mother, born in United States, mothers’ age at intake, welfare recipient, mothers’ own history of abuse, physical health status, psychologically vulnerable index, current depressive symptoms.

Abbreviations: CTS-PC=Parent-Child Conflict Tactics Scales; G=group; N\n=number; NA=not applicable; NR=not reported; ns=not sufficient; SD=standard deviation.

Appendix F Table 4 Parent Self-Reported Outcomes – Corporal Punishment (CTS), Categorical Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | Child Abuse or Neglect, G1 No. (%) | Child Abuse or Neglect, G2 No. (%) | Child Abuse or Neglect, G3 No. (%) | Child Abuse or Neglect, G4 No. (%) | Effect Estimate or Other Outcome Measure
Bugental and Schwartz, 2009^106^ Fair Total N=147 caretakers randomized (N analyzed=94) | Corporal punishment assessed by Conflict Tactics Scale. Measure is dichotomous but analysis was ANOVA. | 1 year | NR (35) | NR (21) | NA | NA | F(1,96)=5.08, p=0.03, n^2^=0.05^*^
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Corporal/verbal punishment on child performed ever in the past week; measured using the parent-child Conflict Tactics Scale (CTS-PC) traditional subscale. This measure included a combination of three items: shout, yell, or scream; spank on bottom with bare hand; and slap on hand, arm, or leg. | 2 years | NR (68) | NR (66) | NA | NA | AOR, 0.92 (95% CI, 0.52 to 1.65, p=0.79)
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Common corporal punishment performed on child ever in the past year; measured using the parent-child CTS-PC revised subscale | 2 years | NR (92) | NR (91) | NA | NA | AOR,.0.80 (95% CI, 0.37 to 1.72, p=0.56)

* Interaction between immigration status and condition was not significant, F(1,96)=2.05, p=0.26. Larger differences in prevalence rates were found for native-born mothers (G2 28% vs. G1 67%) than immigrant mothers (G1 27% vs. G2 18%).

Abbreviations: ANOVA=analysis of variance; AOR=adjusted odds ratio; CI=confidence interval; CTSPC=Parent-Child Conflict Tactics Scales; G=group; N\n=number; NA=not applicable; No.=number; NR=not reported.

Appendix F Table 5 Parent Self-Reported Outcomes – Corporal Punishment (CTS), Continuous Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | CTS Score, G1 Mean (SD) | CTS Score, G2 Mean (SD) | CTS Score, G3 Mean (SD) | CTS Score, G4 Mean (SD) | Effect Estimate or Other Outcome Measure
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Corporal/verbal punishment on child performed ever in the past week; measured using the CTS-PC traditional subscale. This measure included a combination of three items: shout, yell, or scream; spank on bottom with bare hand; and slap on hand, arm, or leg. | 2 years | 4.57 (NR) | 4.02 (NR) | NA | NA | Effect size=0.06, p=0.54
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Common corporal punishment performed on child ever in the past year; measured using the CTS-PC revised subscale | 2 years | 24.17 (NR) | 19.48 (NR) | NA | NA | Effect size=0.20, p < 0.05

Abbreviations: CTS-PC=Parent-Child Conflict Tactics Scales; N=number; NA=not applicable; NR=not reported

Appendix F Table 6 Parent Self-Reported Outcomes – Harsh Parenting (CTS), Categorical Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | Child Abuse or Neglect, G1 No. (%) | Child Abuse or Neglect, G2 No. (%) | Child Abuse or Neglect, G3 No. (%) | Child Abuse or Neglect, G4 No. (%) | Effect Estimate or Other Outcome Measure
Bugental et al, 2002^158^ Unknown study quality^*^ Total N=96 families randomized (N analyzed=NR) | Harsh parenting, assessed on the basis of responses to the CTS assessing the presence or absence of physical abuse (hitting, beating up, kicking, biting, shaking, throwing or tossing child down); administered as a post-program measure | 1 year | NR (26) | NR (23) | NR (4) | NA | Comparing G3 with combined G2/G1: Chi-square 5.52, p<0.05^†^
Bugental et al, 2002^158^ Unknown study quality^*^ Total N=96 families randomized (N analyzed=NR) | Harsh parenting, assessed on the basis of responses to the CTS to assess the presence or absence of legally nonabusive use of force (spanking/slapping); administered as a post-program measure | 1 year | NR^ǂ^ | NR^ǂ^ | NR (7) | NA | Comparing G3 with combined G2/G1: Chi-square 5.04, p<0.05^†^
Fergusson et al, 2005^108^ Fergusson et al, 2013^109^ Fair Total N=443 families randomized (N analyzed=391) | Percentage of parent-reported harsh punishment: A measure was constructed from the CTS-PC, include shaking, hitting with an object, hitting with a fist or kicking, grabbing by the neck/choking, hitting as hard as possible, burning/scalding, throwing/knocking down, and slapping on the head^ǁ^ | Annually from 1 to 6 years, and at 9 years^§^ | NR (20.1) | NR (9.8) | NA | NA | Cohen’s d 0.29 (95% CI, 0.09-0.49) for G2 compared to G1, p<0.01

* This study was excluded from the review for ineligible outcome; quality of the study was not assessed.

† Chi-square analyses were used to compared effects in the cognitive-based extension of HSP home visitation program with the effects from the HSP home visitation and control groups combined.

ǂ G1 and G2 combined: 42%

§ Authors reported that outcome time frame was 0 to 9 years.

ǁ Client families were assessed on a structured interview administered in the clients’ homes by a trained survey interviewer. Interviews typically lasted between 45 minutes to an hour.

Abbreviations: CI=confidence interval; CTS=Conflict Tactics Scales; CTS-PC=Parent-Child Conflict Tactics Scales; G=group; N\n=number; NA=not applicable; NR=not reported; SD=standard deviation.

Appendix F Table 7 Parent Self-Reported Outcomes – Harsh Parenting (CTS and PS), Continuous Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | CTS Score, G1 Mean (SD) | CTS Score, G2 Mean (SD) | CTS Score, G3 Mean (SD) | CTS Score, G4 Mean (SD) | Effect Estimate or Other Outcome Measure
Bugental et al, 2002^158^ Unknown study quality^*^ Total N=96 families randomized (N analyzed=NR) | Harsh parenting, assessed on the basis of responses to the CTS using a frequency scale to assess two categories: physical abuse (hitting, beating up, kicking, biting, shaking, throwing or tossing child down) and legally nonabusive use of force (spanking/slapping); administered as a post-program measure | 1 year | 0.25 (NR) | 0.23 (NR) | 0.06 (NR) | NA | p=0.05^†^
Lam et al, 2009^103^ Fair Total N=30 male patients with their female partners and custodial children randomized (N analyzed=30) | Over-reactivity subscale of the PS, comprising items describing harsh parenting | 12 weeks | Mother: 2.7 (1.4) Father: 3.5 (1.4) | Mother: 2.6 (1.4) Father: 3.0 (1.0) | Mother: 2.2 (1.3) Father: 2.5 (1.0) | NA | Effect size contrasts between PSBCT (G3) and IBT (G1) revealed medium to large effects for fathers’ ratings of over-reactivity, and smaller, yet meaningful effects for mothers’ (r >.20). PSBCT vs. BCT (G2) comparisons at each followup assessment also revealed clinically meaningful differences favoring PSBCT (r>.20). Calculated mean differences not statistically significant.
Lam et al, 2009^103^ Fair Total N=30 male patients with their female partners and custodial children randomized (N analyzed=30) | Over-reactivity subscale of the PS, comprising items describing harsh parenting | 6 months | Mother: 2.9 (1.1) Father: 3.5 (1.2) | Mother: 2.6 (1.2) Father: 3.1 (1.2) | Mother: 2.3 (1.2) Father: 2.6 (1.2) | NA | Calculated mean differences not statistically significant
Lam et al, 2009^103^ Fair Total N=30 male patients with their female partners and custodial children randomized (N analyzed=30) | Over-reactivity subscale of the Parenting Scale (PS), comprising items describing harsh parenting | 1 year | Mother: 3.0 (1.3) Father: 3.5 (1.0) | Mother: 2.7 (1.3) Father: 3.0 (1.0) | Mother: 2.1 (1.2) Father: 2.6. (1.0) | NA | No reported effect sizes, calculated mean difference statistically significant only for fathers at 12 months: −0.9 (95% CI, −1.78 to −0.02)

* This study was excluded from the review for ineligible outcome; quality of the study was not assessed.

† Authors reported significant difference between study groups among high-risk infants within the study: HV plus cognitive group, 0.07 (SD, 0.20) vs. HV standard/control, 0.42 (SD, 0.44); p<0.05.

Abbreviations: BCT=behavioral couples therapy; CI=confidence interval; CTS-PC=Parent-Child Conflict Tactics Scales; G=group; IBT=individual based therapy; N\n=number; NA=not applicable; NR=not reported; PSBCT=parent skills and behavioral couples therapy; PS=parent screening; SD=standard deviation.

Appendix F Table 8 Parent Self-Reported Outcomes – Minor Assault (CTS), Categorical Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | Child Abuse or Neglect, G1 No. (%) | Child Abuse or Neglect, G2 No. (%) | Child Abuse or Neglect, G3 No. (%) | Child Abuse or Neglect, G4 No. (%) | Effect Estimate or Other Outcome Measure
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Mild physical assault on child performed ever in the past year, using the CTS-PC traditional subscale | 2 years | NR (85) | NR (80) | NA | NA | AOR, 0.70 (95% CI, 0.40 to 1.23, p=0.22)

Abbreviations: AOR=adjusted odds ratio; CI=confidence interval; CTS-PC=Parent-Child Conflict Tactics Scales; G=group; N=number; NA=not applicable; NR=not reported.

Appendix F Table 9 Parent Self-Reported Outcomes – Minor Assault (CTS), Continuous Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | CTS Score, G1 Mean (SD) | CTS Score, G2 Mean (SD) | CTS Score, G3 Mean (SD) | CTS Score, G4 Mean (SD) | Effect Estimate or Other Outcome Measure
Dubowitz et al, 2012^147^ Poor Total N=1,119 families randomized (N analyzed=1,119) | CTSPC measuring how parents resolve conflict with children using the minor, severe, and very severe physical assault scales. Minor physical assault included 3 items. Respondents reported the frequency of each item/behavior during the past year (for initial assessment) or past 6 months (for 6-month followup assessment). Weighted scoring was used to give more frequent behavior a higher score. | 6 months | 1.9 (4.6) | 1.8 (4.6) | NA | NA | Effect size=−0.08 (95% CI, −0.22 to 0.05), p=0.245^*^
Dubowitz et al, 2012^147^ Poor Total N=1,119 families randomized (N analyzed=1,119) | CTSPC measuring how parents resolve conflict with children using the minor, severe, and very severe physical assault scales. Minor physical assault included 3 items. Respondents reported the frequency of each item/behavior during the past year (for initial assessment) or past 6 months (for 12-month followup assessment). Weighted scoring was used to give more frequent behavior a higher score. | 12 months | 2.6 (5.6) | 2.1 (4.7) | NA | NA | Effect size=−0.14 (95% CI, −0.28 to ‑0.005, p=0.043^*^
Dubowitz et al, 2012^147^ Poor Total N=1,119 families randomized (N analyzed=558^†^) | Minor physical assault (weighted score on CTS minor physical assault subscale, Parent-Child version) | 3 years | 5 (12.4) | 3.5 (8.3) | NA | NA | p=0.17
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Mild physical assault on child performed ever in the past year, using the CTS-PC traditional subscale | 2 years | 11.93 (NR) | 9.56 (NR) | NA | NA | effect size=0.18, p<0.05

* Multivariate analyses were used and adjusted for family income, mother’s marital status and education, child’s ethnicity and age, and the random effects of participant and practice. Findings for severe and very severe physical assault were extremely low (<1% of sample) and were excluded from the analyses. Initial measures represent an early effect of SEEK, not baseline, due to some SEEK exposure before enrollment in the study.

† Study authors noted that sample sizes for scales varied slightly because of missing values.

Abbreviations: CI=confidence interval; CTS=Conflict Tactics Scales; CTS-PC=Parent-Child Conflict Tactics Scales; G=group; N\n=number; NA=not applicable; NR=not reported.

Appendix F Table 10 Parent Self-Reported Outcomes – Psychological Aggression (CTS), Categorical Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | Child Abuse or Neglect, G1 No. (%) | Child Abuse or Neglect, G2 No. (%) | Child Abuse or Neglect, G3 No. (%) | Child Abuse or Neglect, G4 No. (%) | Effect Estimate or Other Outcome Measure
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Psychological aggression on child performed ever in the past year, using the CTS-PC traditional subscale | 2 years | NR (83) | NR (84) | NA | NA | AOR, 1.10 (95% CI, 0.63 to 1.90, p=0.75)
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Percentage of mothers reporting having committed an act of psychological aggression at least once; based on traditional CTS, include shout, yell or scream; threaten to spank or hit; swear or curse at child; threaten to leave child; call child dumb or lazy | 3 years | NR (89) | NR (88) | NA | NA | NR
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Percentage of mothers reporting having committed assault on child’s self-esteem at least once; based on revised CTS, include four items: swore or cursed at the child, called him/her dumb or lazy, said you would leave him/her, and slapped on the face, head or ears. The first three items traditionally classified as psychological aggression and the last traditionally as severe physical abuse. | 3 years | NR (44) | NR (42) | NA | NA | NR
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=1,060) | Self-reported acts of psychological aggression per CTS-PC: prevalence | 1 year | NR (56.13) | NR (51.18) | NA | NA | p=ns^*^
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=992) | Self-reported acts of psychological aggression per CTS-PC: prevalence | 2 years | NR (77.74) | NR (76.44) | NA | NA | p=ns^*^
DuMont et al, 2010^94^ Good Total N=1,173 mothers randomized (N analyzed=897) | Parental reporting of psychological aggression based on responses on the CTS-PC as reported by mothers during interview | Year 7 of study | NR (86.49) | NR (87.92) | NA | NA | AOR=1.18, p=ns
DuMont et al, 2010^94^ Good Total N=1,173 mothers randomized (N analyzed=793) | Child reporting of psychological aggression based on responses on the Conflict Tactics Scale - Pictured Card version as reported by children during child interview | Year 7 of study | NR (85.14) | NR (84.47) | NA | NA | AOR=1.00, p=ns

* Outcomes reported for prevention subgroup (first-time mothers <19 yo randomly assigned at gestational age of ≤30 wks), psychologically vulnerable subgroup (per index of CES-D and Mastery of Psychological Coping Resources Scale scores). Neither moderates differences between the HFNY and control groups in self-reported psychological aggression.

Abbreviations: AOR=adjusted odds ratio; CI=confidence interval; CTS=Conflict Tactics Scales; CTS-PC=Parent-Child Conflict Tactics Scales; G=group; N\n=number; NA=not applicable; No.=number; NR=not reported; ns=not sufficient.

Appendix F Table 11 Parent Self-Reported Outcomes – Psychological Aggression (CTS), Continuous Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | CTS Score, G1 Mean (SD) | CTS Score, G2 Mean (SD) | CTS Score, G3 Mean (SD) | CTS Score, G4 Mean (SD) | Effect Estimate or Other Outcome Measure
Dubowitz et al, 2012^147^ Poor Total N=1,119 families randomized (N analyzed=1,119) | CTS-PC measuring how parents resolve conflict with children using the psychological aggression scale, with two items. Respondents reported the frequency of each item/behavior during the past year (for initial assessment) or past 6 months (for 6-month followup assessment). Weighted scoring was used to give more frequent behavior a higher score. | 6 months | 6.1 (8.5) | 5.4 (8.6) | NA | NA | Effect size=−0.06 (95% CI, −0.18 to 0.06), p=0.306^*^
Dubowitz et al, 2012^147^ Poor Total N=1,119 families randomized (N analyzed=1,119) | CTS-PC measuring how parents resolve conflict with children using the psychological aggression scale, with two items. Respondents reported the frequency of each item/behavior during the past year (for initial assessment) or past 6 months (for 12-month followup assessment). Weighted scoring was used to give more frequent behavior a higher score. | 12 months | 7.0 (9.3) | 5.7 (8.0) | NA | NA | Effect size=−0.12 (95% CI, −0.24 to −0.002), p=0.047^*^
Dubowitz et al, 2009^148^ Poor Total N=729 parents randomized (N analyzed=558) | Psychological aggression (weighted score on Conflict Tactics Scale psychological aggression subscale, Parent-Child version) | 3 years | 9.1 (16.4) | 7.5 (14.9) | NA | NA | p=0.41
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Psychological aggression on child performed ever in the past year, using the CTS-PC traditional subscale | 2 years | 13.09 (NR) | 11.17 (NR) | NA | NA | Effect size=0.14, p<0.05
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Percentage of mothers reporting having committed an act of psychological aggression at least once; based on traditional CTS, include shout, yell, or scream; threaten to spank or hit; swear or curse at child; threaten to leave child; call child dumb or lazy | 3 years | NR | NR | NA | NA | AOR, 0.76 (95% CI, 0.54 to 1.07, p=0.11)
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Percentage of mothers reporting having committed assault on child’s self-esteem at least once; based on revised CTS, includes four items: swore or cursed at the child, called him/her dumb or lazy, said you would leave him/her, and slapped on the face, head or ears. The first three items traditionally classified as psychological aggression and the last traditionally as severe physical abuse. | 3 years | NR | NR | NA | NA | AOR, 0.90 (95% CI, 0.67-1.20, p=0.46)
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=1,060) | Self-reported acts of psychological aggression per CTS-PC: frequency^†^ | 1 year | 4.74 (NR) | 3.34 (NR) | NA | NA | p=0.007^ǂ^
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=992) | Self-reported acts of psychological aggression per CTS-PC: frequency^†^ | 2 years | 9.84 (NR) | 9.37 (NR) | NA | NA | p=ns^ǂ^
DuMont et al, 2010^94^ Good Total N=1,173 mothers randomized (N analyzed=897) | Parental reporting of psychological aggression based on responses on the CTS-PC as reported by mothers during interview | Year 7 of study | 15.21 (NR) | 15.33 (NR) | NA | NA | Effect size=0.01, p=ns
DuMont et al, 2010^94^ Good Total N=1173 mothers randomized (N analyzed=793) | Child reporting of psychological aggression based on responses on the Conflict Tactics Scale - Pictured Card version as reported by children during child interview | Year 7 of study | 2.68 (NR) | 2.78 (NR) | NA | NA | Effect size=0.05, p=ns
Guterman et al, 2013^183^ Unknown study quality^¶^ Total N=138 families randomized (N analyzed=NR) | CTS-PC psychological aggression subscale that includes items assessing a range of self-reported mother-to-child behaviors, including how many times in the past 6 months (from “never” to “more than 20 times”) the mother shouted, swore, threatened, or cursed at the child^**^ | 6 months | 7.79 (5.91) | 7.27 (6.42) | NA | NA | Difference in Cohen’s D scores for G1 vs. G2: 0.122^#^ Authors reported no significance difference between G1 and G2.

* Multivariate analyses were used and adjusted for family income, mother’s marital status and education, child’s ethnicity and age, and the random effects of participant and practice. Initial measures represent an early effect of SEEK, not baseline, due to some SEEK exposure before enrollment in the study.

† All means are adjusted for prior substantiated reports of child abuse or neglect, 2 dummy codes representing race/ethnicity, random assignment at gestational age 30 weeks or less, site of participation, status as first-time mother, born in United States, mothers’ age at intake, welfare recipient, mothers’ own history of abuse, physical health status, psychologically vulnerable index, and current depressive symptoms.

ǂ Outcomes reported for prevention subgroup (first-time mothers <19 yo randomly assigned at gestational age of ≤30 weeks), psychologically vulnerable subgroup (per index of CES-D and Mastery of Psychological Coping Resources Scale scores). Neither moderates differences between the HFNY and control groups in self-reported psychological aggression.

¶ This study was excluded from the review for ineligible outcome; quality of the study was not assessed.

# Cohen’s D score=(6-month followup mean−baseline mean) / (pooled σ √(2(1−ρ)) Marginally significant decline in self-reported psychological aggression among G2 (time=−1.09, p=0.10).

** Additional information about the subscale scoring was not provided, data collectors were blinded to the random assignment of mothers interviewed, and all sensitive questions were answered privately by respondents, using audio-recorded, computer-assisted self-interviewing technology, whereby mothers listened to each question read to them on headphones, and directly entered their own answers onto the laptop computer, without the data collector’s knowledge of the nature of their response.

Abbreviations: AOR=adjusted odds ratio; CI=confidence interval; CTS=Conflict Tactics Scales; CTS-PC=Parent-Child Conflict Tactics Scales; G=group; N=number; NA=not applicable; NR=not reported; ns=not sufficient; SD=standard deviation.

Appendix F Table 12 Parent Self-Reported Outcomes – Neglect (CTS), Categorical Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | Child Abuse or Neglect, G1 No. (%) | Child Abuse or Neglect, G2 No. (%) | Child Abuse or Neglect, G3 No. (%) | Child Abuse or Neglect, G4 No. (%) | Effect Estimate or Other Outcome Measure
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Neglectful behavior toward child performed by mother ever in the past year; measured using the CTS-PC traditional subscale | 2 years | NR (22) | NR (19) | NA | NA | AOR, 0.81 (95% CI, 0.51 to 1.30, p=0.38)
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Neglectful behavior toward child performed ever in the past year; measured using the CTS-PC revised subscale | 2 years | NR (18) | NR (18) | NA | NA | AOR, 0.97 (95% CI, 0.57 to 1.64, p=0.90)
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Neglect; based on traditional CTS, include being too caught up in one’s problems to express love to the child, inability to provide necessary food, and inability to provide necessary medical care, leaving child at home alone, being too drunk or high to care for child | 3 years | NR (29) | NR (26) | NA | NA | NR
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Neglect; based on revised CTS, includes 3 of the 5 items traditionally categorized as neglect: being too caught up in one’s problems to express love to the child, inability to provide necessary food, and inability to provide necessary medical care | 3 years | NR (27) | NR (22) | NA | NA | NR
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=1,060) | Self-reported acts of neglect per CTS-PC: Prevalence | 1 year | NR (8.27) | NR (5.52) | NA | NA | p=0.07
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=992) | Self-reported acts of neglect per CTS-PC: Prevalence | 2 years | NR (7.18) | NR (8.09) | NA | NA | p=ns
DuMont et al, 2010^94^ Good Total N=1,173 mothers randomized (N analyzed=897) | Parental reporting of neglect based on responses on the Conflict Tactics Scale- Parent Child Version as reported by mothers during interview | Year 7 of study | NR (16.74) | NR (15.77) | NA | NA | AOR, 0.93, p=ns

Abbreviations: AOR=adjusted odds ratio; CI=confidence interval; CTS=Conflict Tactics Scales; CTS-PC=Parent-Child Conflict Tactics Scales; G=group; NA=not applicable; No.=number; NR=not reported.

Appendix F Table 13 Parent Self-Reported Outcomes – Neglect (CTS and MCNS), Continuous Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | CTS Score, G1 Mean (SD) | CTS Score, G2 Mean (SD) | CTS Score, G3 Mean (SD) | CTS Score, G4 Mean (SD) | Effect Estimate or Other Outcome Measure
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Neglectful behavior toward child performed by mother ever in the past year; measured using the CTS-PC traditional subscale | 2 years | 0.75 (NR) | 0.92 (NR) | NA | NA | Effect size=0.05, p=0.74
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Neglectful behavior toward child performed ever in the past year; measured using the CTS-PC revised subscale | 2 years | 0.66 (NR) | 0.65 (NR) | NA | NA | Effect size=0.01, p=0.99
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Neglect; based on traditional CTS, includes being too caught up in one’s problems to express love to the child, inability to provide necessary food, and inability to provide necessary medical care, leaving child at home alone, being too drunk or high to care for child | 3 years | NR | NR | NA | NA | AOR, 0.80 (95% 0.60-1.05, p=0.11)
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Neglect; based on revised CTS, include 3 of the 5 items traditionally categorized as neglect: being too caught up in one’s problems to express love to the child, inability to provide necessary food, and inability to provide necessary medical care | 3 years | NR | NR | NA | NA | AOR, 0.72 (95% 0.54-0.96, p=0.02)
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=1,060) | Self-reported acts of neglect per CTS-PC: frequency^*^ | 1 year | 0.21 (NR) | 0.22 (NR) | NA | NA | p=ns
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=992) | Self-reported acts of neglect per CTS-PC: frequency^*^ | 2 years | 0.46 (NR) | 0.22 (NR) | NA | NA | p=0.08
DuMont et al, 2010^94^ Good Total N=1,173 mothers randomized (N analyzed=897) | Parental reporting of neglect based on responses on the CTS-PC as reported by mothers during interview | Year 7 of study | 0.64 (NR) | 0.53 (NR) | NA | NA | Effect size=0.05, p=ns
Guterman et al, 2013^183^ Unknown study quality^†^ Total N=138 families randomized (N analyzed=NR) | CTS-PC neglect subscale that includes items assessing a range of self-reported mother-to-child behaviors, including how many times in the past 6 months (from”never” to “2 or more times per day”) the mother left the child alone, did not give the child food when needed, or did not take the child to the doctor even when needed^ǂ^ | 6 months | 1.81 (3.03) | 1.29 (3.61) | NA | NA | Cohen’s D score for G1 compared to G2: 0.156 No differences were observed comparing families in G2 with G1 observed after 6 months of service^§^
Guterman et al, 2013^183^ Unknown study quality^†^ Total N=138 families randomized (N analyzed=NR) | MCNS indicates in 11 Likert-type questions the degree to which mothers agree/disagree on a 4-point scale (from 0 “strongly agree” to 4 “strongly disagree”) on statements such as, “When I couldn’t be with my child, I made sure s/he was with someone,” “I made sure my child saw a doctor when s/he needed one,” or “I kept unsafe objects away from my child.”^ǂ^ | 6 months | 11.88 (2.08) | 11.70 (2.23) | NA | NA | Cohen’s D score for G1 compared with G2: 0.083 No significance difference between G1 and G2^§^

* All means are adjusted for prior substantiated reports of child abuse or neglect, 2 dummy codes representing race/ethnicity, random assignment at gestational age 30 wks or less, site of participation, status as first-time mother, born in United States, mothers’ age at intake, welfare recipient, mothers’ own history of abuse, physical health status, psychologically vulnerable index, current depressive symptoms

† This study was excluded from the review for ineligible outcome; quality of the study was not assessed.

ǂ Additional information about the subscale scoring was not provided, data collectors were blinded to the random assignment of mothers interviewed, and all sensitive questions were answered privately by respondents, using audio-recorded, computer-assisted self-interviewing technology, whereby mothers listened to each question read to them on headphones, and directly entered their own answers onto the laptop computer, without the data collector’s knowledge of the nature of their response.

§ Cohen’s D score=(6-month followup mean−baseline mean) / (pooled σ √(2(1−ρ)) Because the CTS-PC Neglect scale was only used at followup, D scores were calculated according to the conventional D score formula comparing means and standard deviations across groups.

Abbreviations: CTS=Conflict Tactics Scales; CTS-PC=Parent-Child Conflict Tactics Scales; G=group; MCNS= Mother–Child Neglect Scale; N=number; NA=not applicable; NR=not reported; ns=not sufficient; SD=standard deviation.

Appendix F Table 14 Parent Self-Reported Outcomes – Physical Abuse (CTS), Categorical Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | Child Abuse or Neglect, G1 No. (%) | Child Abuse or Neglect, G2 No. (%) | Child Abuse or Neglect, G3 No. (%) | Child Abuse or Neglect, G4 No. (%) | Effect Estimate or Other Outcome Measure
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=10,60) | Self-reported acts of very serious physical abuse per CTS-PC: prevalence | 1 year | NR (1.33) | NR (0.93) | NA | NA | p=ns
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=1,060) | Self-reported acts of serious physical abuse per CTS-PC: prevalence | 1 year | NR (0.81) | NR (0.85) | NA | NA | p=ns
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=992) | Self-reported acts of very serious physical abuse per CTS-PC: prevalence | 2 years | NR (2.85) | NR (2.62) | NA | NA | p=ns
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=992) | Self-reported acts of serious physical abuse per CTS-PC: prevalence | 2 years | NR (1.21) | NR (0.60) | NA | NA | p=ns
DuMont et al, 2010^94^ Good Total N=1173 mothers randomized (N analyzed=897) | Parental reporting of serious physical abuse based on responses on the Conflict Tactics Scale-Parent Child version as reported by mothers during interview | Year 7 of study | NR (3.18) | NR (1.76) | NA | NA | AOR=0.55, p=ns^*^

* Analyses control for annual earnings at random assignment and being white.

Abbreviations: AOR=adjusted odds ratio; CTS-PC=Parent-Child Conflict Tactics Scales; N=number; NA=not applicable; NR=not reported; ns=not sufficient.

Appendix F Table 15 Parent Self-Reported Outcomes – Physical Abuse (CTS), Continuous Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | CTS Score, G1 Mean (SD) | CTS Score, G2 Mean (SD) | CTS Score, G3 Mean (SD) | CTS Score, G4 Mean (SD) | Effect Estimate or Other Outcome Measure
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=1,060) | Self-reported acts of very serious physical abuse per CTS-PC: frequency^*^ | 1 year | 0.08 (NR) | 0.01 (NR) | NA | NA | p=0.04
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=1,060) | Self-reported acts of serious physical abuse per CTS-PC: frequency^*^ | 1 year | 0.01 (NR) | 0.01 (NR) | NA | NA | p=ns
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=992) | Self-reported acts of very serious physical abuse per CTS-PC: frequency^*^ | 2 years | 0.13 (NR) | 0.13 (NR) | NA | NA | p=ns
DuMont et al, 2008^93^ Good Total N=1,173 mothers randomized (N analyzed=992) | Self-reported acts of serious physical abuse per CTS-PC: frequency^*^ | 2 years | 0.04 (NR) | 0.01 (NR) | NA | NA | p=0.03
DuMont et al, 2010^94^ Good Total N=1,173 mothers randomized (N analyzed=897) | Parental reporting of serious physical abuse based on responses on the CTS-PC as reported by mothers during interview | Year 7 of study | 0.15 (NR) | 0.03 (NR) | NA | NA | Effect size=−0.20, p<0.01

* All means are adjusted for prior substantiated reports of child abuse or neglect, 2 dummy codes representing race/ethnicity, random assignment at gestational age 30 wks or less, site of participation, status as first-time mother, born in United States, mothers’ age at intake, welfare recipient, mothers’ own history of abuse, physical health status, psychologically vulnerable index, and current depressive symptoms.

Abbreviations: CTS=Conflict Tactics Scales; CTS-PC=Parent-Child Conflict Tactics Scales; G=group; N=number; NA=not applicable; NR=not reported; ns=not sufficient; SD=standard deviation.

Appendix F Table 16 Other Parent Self-Reported Child Abuse or Neglect Outcomes, Categorical Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | Child Abuse or Neglect, G1 No. (%) | Child Abuse or Neglect, G2 No. (%) | Child Abuse or Neglect, G3 No. (%) | Child Abuse or Neglect, G4 No. (%) | Effect Estimate or Other Outcome Measure
Dubowitz et al, 2012^147^ Poor Total N=1,119 families randomized (N analyzed=1,107) | Proportion of families with one or more problems related to possible abuse or neglect documented in the medical records^*^ | From study start to 12 months after | 45 (9) | 85 (14) | NA | NA | OR, 1.14, p=0.76
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Severe assault on child performed ever in the past year, using the CTS-PC traditional subscale | 2 years | NR (7) | NR (9) | NA | NA | AOR, 1.28 (95% CI, 0.41 to 4.00, p=0.67)
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Parental threat to child esteem performed ever in the past year; measured using the CTS-PC revised subscale | 2 years | NR (22) | NR (24) | NA | NA | AOR, 1.17 (95% CI, 0.63 to 2.18, p=0.63)
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Child hit with object by mother ever in the past year; measured using the CTS-PC revised subscale | 2 years | NR (5) | NR (10) | NA | NA | AOR, 2.40 (95% CI, 0.47 to 12.14, p=0.71)
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Extreme physical punishment to child, performed ever in the past year; measured using the CTS-PC revised subscale | 2 years | NR (3) | NR (2) | NA | NA | AOR, 0.75 (95% CI, 0.17 to 3.31, p=0.71)
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Severe physical abuse; based on traditional CTS, include hit somewhere other than bottom with hard object, slap on face, head, or ears, hit with fist or kick hard, throw or knock child down | 3 years | NR (15) | NR (22) | NA | NA | NR
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Very severe physical abuse; based on traditional CTS, include shake child, choke child, burn, or scald on purpose | 3 years | NR (7) | NR (6) | NA | NA | NR
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Extreme physical abuse; based on revised CTS, includes 4 of the 7 items traditionally classified in the severe and very severe physical abuse subscales: hit with fist or kick hard; threw or knocked child down; choked child; and burned or scalded child on purpose | 3 years | NR (2) | NR (4) | NA | NA | NR
Duggan et al, 2004^146^ Poor Total N=730 mothers randomized (N analyzed=NR) | Shook child; based on revised CTS. Authors reported that mothers interpreted this outcome widely, including taking a standing child by the shoulders and shaking gently while making a point verbally | 3 years | NR (7) | NR (6) | NA | NA | NR
DuMont et al, 2010^94^ Good Total N=1,173 mothers randomized (N analyzed=897) | Parental reporting of minor physical aggression based on responses on the CTS-PC as reported by mothers during interview | Year 7 of study | NR (59.17) | NR (64.12) | NA | NA | AOR, 1.25, p=ns
DuMont et al, 2010^94^ Good Total N=1173 mothers randomized (N analyzed=793) | Child reporting of minor physical aggression based on responses on the Conflict Tactics Scale - Pictured Card version as reported by children during child interview | Year 7 of study | NR (77.23) | NR (70.79) | NA | NA | AOR, 0.74, p<0.05
Fergusson et al, 2005^108^ Fergusson et al, 2013^109^ Fair Total N=443 families randomized (N analyzed=391) | Proportion of parents reporting severe physical punishment; on the severe/very severe assault subscales of the CTS-PC | 12, 24, and 36 months | NR (11.7) | NR (4.4) | NA | NA | OR, 0.35 (95% CI, 0.15 to 0.80) for G2 vs. G1 Cohen’s D: 0.26 (95% CI, 0.07 to 0.48) for G2 vs. G1 p<0.01
Kan and Feinberg, 2014^182^ Unknown study quality^†^ Total N=169 couples randomized (N analyzed=NR) | Parent–child physical aggression assessed with the 6-item corporal punishment subscale of the CTS-PC (e.g., shook; hit on bottom with a hard object; slapped on hand, arm, or leg); 7-point scale for each item (ranging from 0 times to more than 20 times) | 3.4 years (average) | NR^ǂ^ | NR^ǂ^ | NA | NA | No significant main effects of treatment condition on parent-child aggression.
LeCroy et al, 2011^184^ Unknown study quality^†^ Total N=195 families randomized (N analyzed=168) | Disciplinary practice (smack/threaten hit) reportedly never used with infants age 6 months to 1 year | 1 year | NR (63.5) | NR (69.5) | NA | NA | p=0.30
LeCroy et al, 2011^184^ Unknown study quality^†^ Total N=195 families randomized (N analyzed=168) | Disciplinary practice (slapped hand) reportedly never used with infants age 6 months to 1 year | 1 year | NR (38.8) | NR (69.5) | NA | NA | p=0.03
LeCroy et al, 2011^184^ Unknown study quality^†^ Total N=195 families randomized (N analyzed=168) | Disciplinary practice (spanked) reportedly never used with infants age 6 months to 1 year | 1 year | NR (65.9) | NR (71.1) | NA | NA | p=0.19
LeCroy et al, 2011^184^ Unknown study quality^†^ Total N=195 families randomized (N analyzed=168) | Disciplinary practice (hit elsewhere) reportedly never used with infants age 6 months to 1 year | 1 year | NR (96.5) | NR (98.8) | NA | NA | p=0.28
LeCroy et al, 2011^184^ Unknown study quality^†^ Total N=195 families randomized (N analyzed=168) | Disciplinary practice (slapped on face) reportedly never used with infants age 6 months to 1 year | 1 year | NR (97.6) | 85^§^ (100) | NA | NA | p=0.99
LeCroy et al, 2011^184^ Unknown study quality^†^ Total N=195 families randomized (N analyzed=168) | Disciplinary practice (threw object at child) reportedly never used with infants age 6 months to 1 year | 1 year | NR (98.8) | 85^§^ (100) | NA | NA | p=0.32
Minkovitz et al, 2007^116^ Fair Total N=2,235 families^ǁ^ (N analyzed=1,308) | Parental response to misbehavior: ever slap in face/spank with object | 5 to 5.5 years | 79 (13) | 74 (11) | NA | NA | AOR, 0.85 (95% CI, 0.60 to 1.22, p=0.40)

* Medical records were reviewed by two medical students. Students were not blinded due to Parent Screening Questionnaires (PSQs) in SEEK children’s records. A study pediatrician met regularly with the students to resolve issues and uncertainties. Reviewers ascertained whether problems occurred before or during SEEK. This outcome measure is based on problems occurring during SEEK. No further information is provided as to what is considered a problem related to possible child abuse or neglect. Authors also did not clarify whether the outcome is verified against review of medical records or reported by parents as part of the PSQ.

† This study was excluded from the review for ineligible outcome; quality of the study was not assessed.

ǂ Authors reported 73.2% mothers overall and 75.6% fathers overall reporting having committed any physical aggression.

§ Calculated based on percentages reported and N analyzed.

ǁ The RCT-only portion of the study originally randomized 2,584 children at birth before enrollment or check for eligibility. Among them, 2,235 children were enrolled into the study.

Abbreviations: AOR=adjusted odds ratio; CI=confidence interval; CTS=Conflict Tactics Scales; CTS-PC=Parent-Child Conflict Tactics Scales; G=group; N=number; NA=not applicable; No.=number; NR=not reported; ns=not sufficient; OR=odds ratio.

Appendix F Table 17 Other Parent Self-Reported Child Abuse or Neglect Outcomes, Continuous Outcome

Author, Year, Quality, Sample Size Analyzed Overall and by Study Group | Outcome Definition | Followup Timing | Instrument Score, G1 Mean (SD) | Instrument Score, G2 Mean (SD) | Instrument Score, G3 Mean (SD) | Instrument Score, G4 Mean (SD) | Effect Estimate or Other Outcome Measure
Barth, 1991^134^ Poor Total N=191 caregiver randomized (N analyzed=191) | CAPI administered to mother, mean score for terms from the three subscales most able to predict abuse (distress, rigidity, unhappiness) | 6 months, or when the child was 4 months old | 93.4 (46.6) | 99.8 (45.8) | NA | NA | p=NS
Barth, 1991^134^ Poor Total N=191 caregiver randomized (N analyzed=191) | Mean CAPI score. Items from the three subscales most able to predict abuse (distress, rigidity, and unhappiness) were used, reducing the number of CAPI items from 77 to 35, which reduced the total possible score from 475 to 221 | Post-test but timing unspecified | 93.37 (46.61) | 99.76 (45.82) | NA | NA | p=NS^*^
Black et al, 1994^157^ Unknown study quality^†^ Total N=60 caregivers randomized (N analyzed=NR) | CAPI, raw scores converted to Z-scores using the normative sample. | 18 months | 1.4 (0.2) | 1.1 (0.2) | NA | NA | G1: CAPI scores were significantly elevated in reference to norms (t=7.43, p<0.01) G2: CAPI scores did not differ from norms Multivariate analysis: G1 and G2 did not differ in their pattern of scores
Dubowitz et al, 2009^148^ Poor Total N=729 parents randomized (N analyzed=558) | Reported instances of severe or very severe physical assault; based on average weighted score on CTS-PC | 3 years | 0.33 (1.96) | 0.11 (0.75) | NA | NA | p=0.04
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Severe assault on child performed ever in the past year, using the CTS-PC traditional subscale | 2 years | 0.3 (NR) | 0.41 (NR) | NA | NA | Effect size=0.05, p=0.68
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Parental threat to child esteem performed ever in the past year; measured using the CTS-PC revised subscale | 2 years | 0.64 (NR) | 0.95 (NR) | NA | NA | Effect size=0.14, p=0.30
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Child hit with object by mother ever in the past year; measured using the CTS-PC revised subscale | 2 years | 0.46 (NR) | 0.33 (NR) | NA | NA | Effect size=0.06, p=0.66
Duggan et al, 2007^91^ Good Total N=364 families randomized (N analyzed=249) | Extreme physical punishment to child, performed ever in the past year; measured using the CTS-PC revised subscale | 2 years | 0.04 (NR) | 0.19 (NR) | NA | NA | Effect size=0.14, p=0.18
DuMont et al, 2010^94^ Good Total N=1,173 mothers randomized (N analyzed=897) | Parental reporting of minor physical aggression based on responses on the CTS-PC as reported by mothers during interview^ǂ^ | Year 7 of study | 4.51 (NR) | 4.26 (NR) | NA | NA | Effect size=−0.02, p=ns
DuMont et al, 2010^94^ Good Total N=1,173 mothers randomized (N analyzed=793) | Child reporting of minor physical aggression based on responses on the Conflict Tactics Scale - Pictured Card version as reported by children during child interview^ǂ^ | Year 7 of study | 2.35 (NR) | 2.27 (NR) | NA | NA | Effect size=−0.04, p=ns
Fraser et al, 2000^161^ Unknown study quality^†^ Total N=181 families randomized (N analyzed=NR) | Child abuse risk; beliefs associated with parental maltreatment of children were measured using the CAPI. | 18 months | 140.89 (113.40) | 106.41 (73.67) | NA | NA | Post-hoc paired t-tests indicated a significant reduction between baseline (M=11.40, SD=3.13) and 7 months (M=10.46, SD=3.34) in the intervention group, [t(77)=3.16, p<0.03]; the reduction in score was maintained at 18 months.
Guterman et al, 2013^183^ Unknown study quality^†^ Total N=138 families randomized (N analyzed=NR) | CTS-PC physical aggression subscale that includes items assessing a range of self-reported mother-to-child behaviors, including how many times in the past 6 months (from “never” to “more than 20 times”) the mother shook the child; pinched him/her; slapped him/her on the head, face, or ears^§^ | 6 months | 4.54 (4.03) | 4.08 (4.17) | NA | NA | Difference in Cohen’s D scores for G1 compared with G2: 0.185 No significant difference between G1 and G2^ǁ^
Kan and Feinberg, 2014^182^ Unknown study quality^†^ Total N=169 couples randomized (N analyzed=NR) | Parent–child physical aggression assessed with the 6-item corporal punishment subscale of the CTS-PC (e.g., shook; hit on bottom with a hard object; slapped on hand, arm, or leg); 7-point scale for each item (ranging from 0 times to more than 20 times); frequency scores for each parent were calculated by recoding each item as the midpoint of the response category and summing across items | 3.4 years (average) | NR^¶^ | NR^¶^ | NA | NA | Authors reported no significant main effects of treatment condition on parent-child aggression
LeCroy et al, 2011^184^ Unknown study quality^†^ Total N=195 families randomized (N analyzed=168) | Count of aggressive discipline practices based on a modified version of the Revised Parent-Child CTS, a short version using the most serious indicators of abusive and neglectful behavior | 1 year | 1.83 (0.16) | 1.44 (0.16) | NA | NA | F=2.67 (1, 188), p=0.10
Nair et al, 2003^185^ Unknown study quality^†^ Total N=161 caregivers randomized (N analyzed=NR) | CAPI total score^#^ | 6 months | 176.4 (132.9) | 195 (103.9) | NA | NA | NR
Nair et al, 2003^185^ Unknown study quality^†^ Total N=161 caregivers randomized (N analyzed=NR) | CAPI total score^#^ | 18 months | 166.2 (99.4) | 181.7 (99.7) | NA | NA | NR
Olds et al, 1986^98^ Fair Total N=400 families randomized (N analyzed=NR) | Average number of times spanked or hit in the last 2 weeks | 6 months | 1.09 (NR) | 1.71 (NR) | 0.9 (NR) | NA | Mean difference (SD) for G3 vs. G1: 0.9 (1.71), p=NS^**^
Reedtz et ai, 2011^186^ Unknown study quality^†^ Total N= randomized unclear (N analyzed=189) | Parenting Practices Interview Harsh Discipline subscale | 12 months | 1.76 (0.40) | 1.86 (0.39) | NA | NA | F_1, 183_ (ƞ^2^): 9.9 (0.05), p<0.01
Silovsky et al, 2011^111^ Fair Total N=105 caregivers randomized (N analyzed=105) | CAPI score | 17 months | 128.3 (103.3) | 168.6 (107.2) | NA | NA | G1 17-month change: 28.2 (SD: 11.2), p<0.05 G2 17-month change: 39.0 (SD: 12.9), p<0.001 Between group r2=0.89; 17-month G1-G2 change: −10.8 (SD: 17.1), p=NS
Silovsky et al, 2011^111^ Fair Total N=105 caregivers randomized (N analyzed=105) | CAPI score | 10 months | 170.8 (109.3) | 166.5 (105.0) | NA | NA | G1 10-month change: 15.0 (SD: 11.9), p=NS G2 10-month change: 42.4 (SD: 11.8), p<0.001 Between group r2=0.89; 10-month G1-G2 change: −27.5 (SD: 16.7), p<0.10

* Reporting of between-group post-test differences in CAPI is unclear. Table 2 footnote states that “No between group differences in post-tests are significant,” but this may be only referring to a combined “parental wellness” variable, which includes CAPI along with three other scales (CES-D, STAI, Pearlin Mastery Scale).

† This study was excluded from the review for ineligible outcome; quality of the study was not assessed.

ǂ Analyses control for annual earnings at random assignment and being white.

§ Additional information about the subscale scoring was not provided, data collectors were blinded to the random assignment of mothers interviewed, and all sensitive questions were answered privately by respondents, using audio-recorded, computer assisted self-interviewing technology, whereby mothers listened to each question read to them on headphones, and directly entered their own answers onto the laptop computer, without the data collector’s knowledge of the nature of their response.

ǁ Cohen’s D score=(6-month followup mean−baseline mean) / (pooled σ √(2(1−ρ))

Significant decline in physical assault in G2 (time=−1.23, p=0.05) from baseline to six-month followup point but no significant decline in G1.

¶ Parent-child physical frequency (based on raw/nonimputed data): Mothers (overall): 10.87 (14.37); Fathers (overall): 10.06 (12.95).

# Authors reported outcomes of subgroups categorized by number of environmental risk factors: 0–2 risks, 3 risks, 4 risks, 5 or more risks. Risk were depression, domestic violence, nondomestic violence, family size, homelessness, incarceration, absence of significant other in home, negative life events, psychiatric symptomatology, severity of drug use.

** Analysis adjusted for boyfriend/husband support and maternal sense of control.

Abbreviations: CAPI=Child Abuse Potential Inventory; CTS=Conflict Tactics Scales; G=group; N=number; NA=not applicable; NR=not reported; NS=not sufficient; SD=standard deviation.